# References

1 Edelstein BL. Evidence-based dental care for children and the age 1 dental visit. Pediatr Ann. 1998;27:569-574. [pmid: 9778708].
2 Newacheck PW, Hughes DC, Hung YY, Wong S, Stoddard JJ. The unmet health needs of America's children. Pediatrics. 2000;105:989-997. [pmid: 10742361].
3 Caufield PW, Griffen AL. Dental caries. An infectious and transmissible disease. Pediatr Clin North Am. 2000;47:1001–1019, v.
4 U.S. Department of Health and Human Services. Oral Health in America: a Report of the Surgeon General. Rockville, Md: USDHHS, National Institute of Dental and Craniofacial Research; 2000;Pub No 00-4713.
5 Vargas CM, Crall JJ, Schneider DA. Sociodemographic distribution of pediatric dental caries: NHANES III, 1988-1994. J Am Dent Assoc. 1998;129:1229-1238. [pmid: 9766104].
6 Ismail AI, Sohn W. A systematic review of clinical diagnostic criteria of early childhood caries. J Public Health Dent. 1999;59:171-191. [pmid: 10649590].
7 Kaste LM, Selwitz RH, Oldakowski RJ, Brunelle JA, Winn DM, Brown LJ. Coronal caries in the primary and permanent dentition of children and adolescents 1–17 years of age: United States, 1988-1991. J Dent Res. 1996;75(Spec No):631-641. [pmid: 8594087].
8 Mouradian WE, Wehr E, Crall JJ. Disparities in children's oral health and access to dental care. JAMA. 2000;284:2625-2631. [pmid: 11086371].
9 Kaste LM, Drury TF, Horowitz AM, Beltran E. An evaluation of NHANES III estimates of early childhood caries. J Public Health Dent. 1999;59:198-200. [pmid: 10649592].
10 Brown LJ, Wall TP, Lazar V. Trends in untreated caries in primary teeth of children 2 to 10 years old. J Am Dent Assoc. 2000;131:93-100. [pmid: 10649880].
11 Edelstein BL , Young children. Dental Care Considerations of Disadvantaged and Special Care Populations. In: Bonito AJ, Cooper LY, (Eds). Rockville, MD: Bureau of Health Professions, Health Resources and Services Administration; 2001.
12 Sheller B, Williams BJ, Lombardi SM. Diagnosis and treatment of dental caries-related emergencies in a children's hospital. Pediatr Dent. 1997;19:470-475. [pmid: 9442540].
13 Acs G, Shulman R, Ng MW, Chussid S. The effect of dental rehabilitation on the body weight of children with early childhood caries. Pediatr Dent. 1999;21:109-113. [pmid: 10197335].
14 Thomas CW, Primosch RE. Changes in incremental weight and well-being of children with rampant caries following complete dental rehabilitation. Pediatr Dent. 2002;24:109-113. [pmid: 11991312].
15 Gift HC, Reisine ST, Larach DC. The social impact of dental problems and visits. Am J Public Health. 1992;82:1663-1668. [pmid: 1456343]. [pmcid: 1694558].
16 Edelstein BL. Public and clinical policy considerations in maximizing children's oral health. Pediatr Clin North Am. 2000;47:1177–1189, vii.
17 Greenwell AL, Johnsen D, DiSantis TA, Gerstenmaier J, Limbert N. Longitudinal evaluation of caries patterns form the primary to the mixed dentition. Pediatr Dent. 1990;12:278-282. [pmid: 2095537].
18 Bader J, ed. Risk assessment in dentistry: proceedings of a conference. Chapel Hill, NC: University of North Carolina Department of Dental Ecology; 1990.
19 Davey KW. Effect of premature loss of primary molars on the anteroposterior position of maxillary first permanent molars and other maxillary teeth. J Dent Child. 1967;34:383-394. [pmid: 5341573].
20 Featherstone JD. The science and practice of caries prevention. J Am Dent Assoc. 2000;131:887-899. [pmid: 10916327].
21 Soderling E, Isokangas P, Pienihakkinen K, Tenovuo J, Alanen P. Influence of maternal xylitol consumption on mother-child transmission of mutans streptococci: 6-year follow-up. Caries Res. 2001;35:173-177. [pmid: 11385196].
22 Brambilla E, Felloni A, Gagliani M, Malerba A, Garcia-Godoy F, Strohmenger L. Caries prevention during pregnancy: results of a 30-month study. J Am Dent Assoc. 1998;129:871-877. [pmid: 9685762].
23 American Dental Association, Council on Access, Prevention, and Interprofessional Relations. Caries diagnosis and risk assessment: a review of preventive strategies and management. J Am Dent Assoc. 1995;126(suppl):1s-24s. [pmid: 7790681].
24 Lewis DW, Ismail AI. Periodic health examination, 1995 update: 2. Prevention of dental caries. The Canadian Task Force on the Periodic Health Examination. CMAJ. 1995;152:836-846. [pmid: 7697577]. [pmcid: 1337757].
25 American Academy of Pediatric Dentistry. Guidelines for fluoride therapy. Reference Manual, 2000-2001. Web Page. Available at: http://www.aapd.org/.
26 Scottish Intercollegiate Guidelines Network (SIGN). Preventing dental caries in children at high caries risk: Targeted prevention of dental caries in the permanent teeth of 6–16 year olds presenting for dental care. Edinburgh, UK: Royal College of Physicians; 2000.
27 Centers for Disease Control and Prevention (CDC). Recommendations for using fluoride to prevent and control dental caries in the United States. Morb Mortal Wkly Rep. 2001;50(RR-14):1042.
28 Horowitz AM, Selwitz RH, Kleiman DV, Ismail AI, Bader JD. NIH Consensus Development Conference on Diagnosis and Management of Dental Caries Throughout Life. J Dent Educ. 2001;10:940-1179.
29 Task Force on Community Preventive Services. Recommendations regarding selected interventions to prevent dental caries, oral and pharyngeal cancers, and sports-related craniofacial injury. Am J Prev Med. 2002;In press.
30 American Academy of Pediatrics. Practice guideline endorsement. Recommendations for Using Fluoride to Prevent and Control Dental Caries in the United States. Available at: http://www.aap.org/policy/fluoride.html.
31 Truman BI, Gooch BF, Sulemana I, et al. Reviews of evidence on interventions to prevent dental caries, oral and pharyngeal cancers, and sports-related craniofacial injuries. Am J Prev Med. 2002;23:21-54. [pmid: 12091093].
32 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
33 Edelstein BL. The age one dental visit: information on the web. Pediatr Dent. 2000;22:163-164. [pmid: 10769866].
34 Casamassimo P. Bright Futures in Practice: Oral Health. Arlington, Va: National Center for Education in Maternal and Child Health; 1996.
35 Edelstein BL, Manski RJ, Moeller JF. Pediatric dental visits during 1996: an analysis of the federal Medical Expenditure Panel Survey. Pediatr Dent. 2000;22:17-20. [pmid: 10730281].
36 General Accounting Office. Oral health: factors contributing to low use of dental services by low-income populations. Report No. GAO/HEHS-00-72. Washington, DC: GAO; 2000.
37 General Accounting Office. Oral health: dental disease is a chronic problem among low-income propulations. Report No. GAO/HEHS-00-72. Washington, DC: GAO; 2000.
38 Cashion SW, Vann WF Jr, Rozier RG, Venezie RD, McIver FT. Children's utilization of dental care in the NC Medicaid program. Pediatr Dent. 1999;21:97-103. [pmid: 10197333].
39 McCormick MC, Kass B, Elixhauser A, Thompson J, Simpson L. Annual report on access to and utilization of health care for children and youth in the United States—1999. Pediatrics. 2000;105:219-230. [pmid: 10617727].
40 Ismail AI, Bandekar RR. Fluoride supplements and fluorosis: a meta-analysis. Community Dent Oral Epidemiol. 1999;27:48-56. [pmid: 10086926].
41 Serwint JR, Mungo R, Negrete VF, Duggan AK, Korsch BM. Child-rearing practices and nursing caries. Pediatrics. 1993;92:233-237. [pmid: 8337022].
42 Beltran ED, Malvitz DM, Eklund SA. Validity of two methods for assessing oral health status of populations. J Public Health Dent. 1997;57:206-214. [pmid: 9558624].
43 Powell LV. Caries risk assessment: relevance to the practitioner. J Am Dent Assoc. 1998;129:349-353. [pmid: 9529810].
44 Pitts NB. Risk assessment and caries prediction. J Dent Educ. 1998;62:762-770. [pmid: 9847880].
45 McCunniff MD, Damiano PC, Kanellis MJ, Levy SM. The impact of WIC dental screenings and referrals on utilization of dental services among low-income children. Pediatr Dent. 1998;20:181-187. [pmid: 9635314].
46 Bentley EM, Holloway PJ. An evaluation of the role of health visitors in encouraging dental attendance of infants. Community Dent Health. 1993;10:243-249. [pmid: 8269339].
47 Margolis FJ, Burt BA, Schork MA, Bashshur RL, Whittaker BA, Burns TL. Fluoride supplements for children. A survey of physicians' prescription practices. Am J Dis Child. 1980;134:865-868. [pmid: 7416113].
48 Siegel C, Gutgesell ME. Fluoride supplementation in Harris County, Texas. Am J Dis Child. 1982;136:61-63. [pmid: 7055110].
49 Gift HC, Milton B, Walsh V. Physicians and caries prevention. Results of a physician survey on preventive dental services. JAMA. 1984;252:1447-1448. [pmid: 6471271].
50 Rigilano JC, Friedler EM, Ehemann LJ. Fluoride prescribing patterns among primary care physicians. J Fam Pract. 1985;21:381-385. [pmid: 4056672].
51 Levy SM. Systemic fluoride supplementation in an academic family practice setting. J Fam Pract. 1987;24:532, 534, 536.
52 Kuthy RA, McTigue DJ. Fluoride prescription practices of Ohio physicians. J Public Health Dent. 1987;47:172-176. [pmid: 3478487].
53 Margolis FJ, Chesney BK, Schork A. Fluoride supplements. Changes in physicians' attitudes and practices following an intensive, multifaceted educational program. Am J Dis Child. 1987;141:72-76. [pmid: 3788885].
54 Dillenberg JS, Levy SM, Schroeder DC, Gerston EN, Andersen CJ. Arizona providers' use and knowledge of fluoride supplements. Clin Prev Dent. 1992;14:15-26. [pmid: 1291183].
55 Jones KF, Berg JH. Fluoride supplementation. A survey of pediatricians and pediatric dentists. Am J Dis Child. 1992;146:1488-1491. [pmid: 1456266].
56 Roberts MW, Keels MA, Sharp MC, Lewis JL Jr. Fluoride supplement prescribing and dental referral patterns among academic pediatricians. Pediatrics. 1998;101:E6. [pmid: 9417170].
57 Pinkerton RE, Tinanoff N, Willms JL, Tapp JT. Resident physician performance in a continuing education format. Does newly acquired knowledge improve patient care?. JAMA. 1980;244:2183-2185. [pmid: 7420722].
58 Messimer S, Hickner J. Oral fluoride supplementation: improving practitioner compliance by using a protocol. J Fam Pract. 1983;17:821-825. [pmid: 6631346].
59 Levy SM, Kiritsy MC, Slager SL, Warren JJ. Patterns of dietary fluoride supplement use during infancy. J Public Health Dent. 1998;58:228-233. [pmid: 10101699].
60 Widenheim J. A time-related study of intake pattern of fluoride tablets among Swedish preschoolchildren and parental attitudes. Community Dent Oral Epidemiol. 1982;10:296-300. [pmid: 6961977].
61 Fanning EA, Cellier KM, Leadbeater MM, Somerville CM. South Australian kindergarten children: fluoride tablet supplements and dental caries. Aust Dent J. 1975;20:7-9. [pmid: 1057890].
62 Richardson AS. Parental participation in the administration of fluoride supplements. Can J Public Health. 1967;58:508-513. [pmid: 6077085].
63 Hamberg L. Controlled trial of fluoride in vitamin drops for prevention of caries in children. Lancet. 1971;1:441-442. [pmid: 4100412].
64 Hennon DK, Stookey GK, Muhler JC. Prophylaxis of dental caries: relative effectiveness of chewable fluoride preparations with and without added vitamins. J Pediatr. 1972;80:1018-1021. [pmid: 5026023].
65 Margolis FJ, Reames HR, Freshman E, MaCauley CD, Mehaffey H. Flouride. Ten-year prospective study of deciduous and permanent dentition. Am J Dis Child. 1975;129:794-800. [pmid: 1096595].
66 Hennon DK, Stookey GK, Beiswanger BB. Fluoride-vitamin supplements: effects on dental caries and fluorosis when used in areas with suboptimum fluoride in the water supply. J Am Dent Assoc. 1977;95:965-971. [pmid: 269878].
67 Hu D, Wan H, Li S. The caries-inhibiting effect of a fluoride drop program: a 3-year study on Chinese kindergarten children. Chin J Dent Res. 1998;1:17-20. [pmid: 10557167].
68 Lin YT, Tsai CL. Comparative anti-caries effects of tablet and liquid fluorides in cleft children. J Clin Dent. 2000;11:104-106. [pmid: 11460274].
69 Horowitz HS. The role of dietary fluoride supplements in caries prevention. J Public Health Dent. 1999;59:205-210. [pmid: 10682325].
70 Eklund SA, Burt BA, Ismail AI, Calderone JJ. High-fluoride drinking water, fluorosis, and dental caries in adults. J Am Dent Assoc. 1987;114:324-328. [pmid: 3470353].
71 McDonagh M, Whiting P, Bradley M, Cooper J, Sutton A, Chestnutt I, Misso K, Wilson P, Treasure E, and Kleijnen J. A systematic review of public warter flurodiation. NHS Centre for Reviews and Dissemination, University of New York. September, 2000; accessed August 28, 2002. Web Page. Available at: http://www.york.ac.uk/inst/crd/fluorid.pdf.
72 Beltran-Aguilar ED, Griffin SO, Lockwood SA. Prevalence and trends in enamel fluorosis in the United States from the 1930s to the 1980s. J Am Dent Assoc. 2002;133:157-165. [pmid: 11868834].
73 Clark DC. Trends in prevalence of dental fluorosis in North America. Community Dent Oral Epidemiol. 1994;22:148-152. [pmid: 8070241].
74 Ad Hoc Committee on Fluoride, Committee to Coordinate Environmental Health and Related Programs; Review of Fluoride: Benefits and Risks. Washington, DC: Piblic Health Service, US Department of Health and Human Services.1991.
75 Rozier RG. The prevalence and severity of enamel fluorosis in North American children. J Public Health Dent. 1999;59:239-246. [pmid: 10682330].
76 Pendrys DG. Risk of enamel fluorosis in nonfluoridated and optimally fluoridated populations: considerations for the dental professional. J Am Dent Assoc. 2000;131:746-755. [pmid: 10860326].
77 Rozier RG. Effectiveness of methods used by dental professionals for the primary prevention of dental caries. J Dent Educ. 2001;65:1063-1072. [pmid: 11699978].
78 Lewis CW, Grossman DC, Domoto PK, Deyo RA. The role of the pediatrician in the oral health of children: A national survey. Pediatrics. 2000;106:E84. [pmid: 11099627].
79 Warren DP, Henson HA, Chan JT. Dental hygienist and patient comparisons of fluoride varnishes to fluoride gels. J Dent Hyg. 2000;74:94-101. [pmid: 11314061].
80 Autio-Gold JT, Courts F. Assessing the effect of fluoride varnish on early enamel carious lesions in the primary dentition. J Am Dent Assoc. 2001;132:1247-1253. quiz 1317–1318. [pmid: 11665349].
81 Beltran-Aguilar ED, Goldstein JW, Lockwood SA. Fluoride varnishes. A review of their clinical use, cariostatic mechanism, efficacy and safety. J Am Dent Assoc. 2000;131:589-596. [pmid: 10832252].
82 Ekstrand J, Koch G, Petersson LG. Plasma fluoride concentration and urinary fluoride excretion in children following application of the fluoride-containing varnish Duraphat. Caries Res. 1980;14:185-189. [pmid: 6929729].
83 Ekstrand J, Koch G, Lindgren LE, Petersson LG. Pharmacokinetics of fluoride gels in children and adults. Caries Res. 1981;15:213-220. [pmid: 6938306].
84 Sgan-Cohen HD, Mansbach IK, Haver D, Gofin R. Community-oriented oral health promotion for infants in Jerusalem: evaluation of a program trial. J Public Health Dent. 2001;61:107-113. [pmid: 11474913].
85 Brown LF. Research in dental health education and health promotion: a review of the literature. Health Educ Q. 1994;21:83-102. [pmid: 8188495].
86 Sprod AJ, Anderson R, Treasure E. Effective oral health promotion. Health Promotion Wales; 1996;Technical Report 20.
87 Kay EJ, Locker D. Is dental health education effective? A systematic review of current evidence. Community Dent Oral Epidemiol. 1996;24:231-235. [pmid: 8871028].
88 Kay E, Locker D. A systematic review of the effectiveness of health promotion aimed at improving oral health. Community Dent Health. 1998;15:132-144. [pmid: 10645682].
89 Holt RD, Winter GB, Fox B, Askew R. Second assessment of London children involved in a scheme of dental health education in infancy. Community Dent Oral Epidemiol. 1989;17:180-182. [pmid: 2758790].
90 Ekman A, Persson B. Effect of early dental health education for Finnish immigrant families. Swed Dent J. 1990;14:143-151. [pmid: 2255993].
91 Rayner JA. A dental health education programme, including home visits, for nursery school children. Br Dent J. 1992;172:57-62. [pmid: 1739501].
92 Fiset L, Grembowski D, Del Aguila M. Third-party reimbursement and use of fluoride varnish in adults among general dentists in Washington State. J Am Dent Assoc. 2000;131:961-968. [pmid: 10916334].
93 Schneider. Personal Communication. 2001.
94 Grodzka K, Augustyniak L, Budny J, et al. Caries increment in primary teeth after application of Duraphat fluoride varnish. Community Dent Oral Epidemiol. 1982;10:55-59. [pmid: 6952970].
95 Petersson LG, Twetman S, Pakhomov GN. The efficiency of semiannual silane fluoride varnish applications: a two-year clinical study in preschool children. J Public Health Dent. 1998;58:57-60. [pmid: 9608447].
96 Holm AK. Effect of fluoride varnish (Duraphat) in preschool children. Community Dent Oral Epidemiol. 1979;7:241-245. [pmid: 295702].
97 Frostell G, Birkhed D, Edwardsson S, et al. Effect of partial substitution of invert sugar for sucrose in combination with Duraphat treatment on caries development in preschool children: the Malmo Study. Caries Res. 1991;25:304-310. [pmid: 1913770].
98 Helfenstein U, Steiner M. A note concerning the caries preventive effect of Duraphat. Community Dent Oral Epidemiol. 1994;22:6-7. [pmid: 8143445].
99 Helfenstein U, Steiner M. Fluoride varnishes (Duraphat): a meta-analysis. Community Dent Oral Epidemiol. 1994;22:1-5. [pmid: 8143435].
100 van Rijkom HM, Truin GJ, van 't Hof MA. A meta-analysis of clinical studies on the caries-inhibiting effect of fluoride gel treatment. Caries Res. 1998;32:83-92. [pmid: 9544855].
101 Marinho VC, Higgins JP, Logan S, Sheiham A. Fluoride gels for preventing dental caries in children and adolescents. Cochrane Database Syst Rev. 2002;CD002280.
102 Roberts GJ, Roberts IF. Dental disease in chronically sick children. ASDC J Dent Child. 1981;48:346-351. [pmid: 6946073].
103 Feigal RJ, Gleeson MC, Beckman TM, Greenwood ME. Dental caries related to liquid medication intake in young cardiac patients. ASDC J Dent Child. 1984;51:360-362. [pmid: 6592188].
104 National Institutes of Health. Diagnosis and management of dental caries throughout life. NIH Consensus Statement. 2001;2001:1-30.
105 Margolis FJ, Macauley J, Freshman E. The effects of measured doses of fluoride. A five-year preliminary report. Am J Dis Child. 1967;113:670-672. [pmid: 4381737].
106 Twetman S, Petersson LG, Pakhomov GN. Caries incidence in relation to salivary mutans streptococci and fluoride varnish applications in preschool children from low- and optimal-fluoride areas. Caries Res. 1996;30:347-353. [pmid: 8877088].
107 Awad MA, Hargreaves JA, Thompson GW. Dental caries and fluorosis in 7–9 and 11–14 year old children who received fluoride supplements from birth. J Can Dent Assoc. 1994;60:318-322. [pmid: 8187045].
108 Kalsbeek H, Verrips E, Dirks OB. Use of fluoride tablets and effect on prevalence of dental caries and dental fluorosis. Community Dent Oral Epidemiol. 1992;20:241-245. [pmid: 1424540].
109 Widenheim J, Birkhed D. Caries-preventive effect on primary and permanent teeth and cost- effectiveness of an NaF tablet preschool program. Community Dent Oral Epidemiol. 1991;19:88-92. [pmid: 1904806].
110 D'Hoore W, Van Nieuwenhuysen JP. Benefits and risks of fluoride supplementation: caries prevention versus dental fluorosis. Eur J Pediatr. 1992;151:613-616. [pmid: 1505582].
111 Mann J, Horesh E, Ran F, Gedalia I. The effect of fluoride drop administration on dental caries increment—a longitudinal study. Isr J Dent Sci. 1989;2:148-152. [pmid: 2490929].
112 de Liefde B, Herbison GP. The prevalence of development defects of enamel and dental caries in New Zealand children receiving differing fluoride supplementation, in 1982 and 1985. N Z Dent J. 1989;85:2-8. [pmid: 2783769].
113 Bagramian RA, Narendran S, Ward M. Relationship of dental caries and fluorosis to fluoride supplement history in a non-fluoridated sample of schoolchildren. Adv Dent Res. 1989;3:161-167. [pmid: 2640427].
114 O'Rourke CA, Attrill M, Holloway PJ. Cost appraisal of a fluoride tablet programme to Manchester primary schoolchildren. Community Dent Oral Epidemiol. 1988;16:341-344. [pmid: 3144446].
115 Widenheim J, Birkhed D, Granath L, Lindgren G. Preeruptive effect of NaF tablets on caries in children from 12 to 17 years of age. Community Dent Oral Epidemiol. 1986;14:1-4. [pmid: 3456867].
116 Petersson LG, Koch G, Rasmusson CG, Stanke H. Effect on caries of different fluoride prophylactic programs in preschool children. A two year clinical study. Swed Dent J. 1985;9:97-104. [pmid: 3895545].
117 Friis-Hasche E, Bergmann J, Wenzel A, Thylstrup A, Pedersen KM, Petersen PE. Dental health status and attitudes to dental care in families participating in a Danish fluoride tablet program. Community Dent Oral Epidemiol. 1984;12:303-307. [pmid: 6593149].
118 Holm AK, Andersson R. Enamel mineralization disturbances in 12-year-old children with known early exposure to fluorides. Community Dent Oral Epidemiol. 1982;10:335-339. [pmid: 6961984].
119 Fanning EA, Cellier KM, Somerville CM. South Australian kindergarten children: effects of fluoride tablets and fluoridated water on dental caries in primary teeth. Aust Dent J. 1980;25:259-263. [pmid: 6936002].
120 Thylstrup A, Fejerskov O, Bruun C, Kann J. Enamel changes and dental caries in 7-year-old children given fluoride tablets from shortly after birth. Caries Res. 1979;13:265-276. [pmid: 288511].
121 Granath LE, Rootzen H, Liljegren E, Holst K, Kohler L. Variation in caries prevalence related to combinations of dietary and oral hygiene habits and chewing fluoride tablets in 4-year-old children. Caries Res. 1978;12:83-92.
122 Andersson R, Grahnen H. Fluoride tablets in pre-school-age—effect on primary and permanent teeth. Sven Tandlak Tidskr. 1976;69:137-143. [pmid: 1068536].
123 Aasenden R, Peebles TC. Effects of fluoride supplementation from birth on human deciduous and permanent teeth. Arch Oral Biol. 1974;19:321-326. [pmid: 12692915].
124 Pritchard JL. The pre-natal and post-natal effects of fluoride supplements on West Australian school children aged 6, 7, and 8, Perth, 1967. Austral Dent J. 1967;14:335-338.
125 Kailis DG, Taylor SR, Davis GB, et al. Fluoride and caries: observations on the effects of prenatal and postnatal fluoride on some Perth pre-school children. Med J Aust. 1968;2:1037-1040. [pmid: 4387292].
126 Hennon DK, Stookey GK, Muhler JC. The clinical anticariogenic effectiveness of supplementary fluoride-vitamin preparations—results at the end of four years. J Dent Child. 1967;34:439-443. [pmid: 4383721].
127 Minoguchi G, Ono T, Tamai S. Prophylactic application of fluoride for dental caries in Japan. Internat Dent J. 1963;13:510-515.
128 Arnold FA, McClure FJ, White CL. Sodium fluoride tables for children. Dent Prog. 1960;1:8-12.