# Discussion

This section summarizes the strength of the evidence as well as the general findings for each of the key questions. Our approach to rating the strength of the evidence follows the current Task Force methods, in that we indicate the explicit reason(s) for each strength rating rather than rely on a fixed set of criteria. ^21^ The ratings used are “good,” “fair,” and “poor,” and they take into account the aggregate internal validity, the aggregate external validity, and the coherence and consistency of the evidence.

## Screening Accuracy

The strength of the evidence addressing the accuracy of visual oral screening examinations by primary care clinicians is poor. It consists of 2 case studies in which single PCCs identified caries lesions with an accuracy approaching that of dentists. The studies were consistent, but their formats raise substantial external validity issues.

No evidence is available for the accuracy with which PCCs can identify children at elevated risk of dental caries. Among preschool children, the strongest clinical predictor of future caries is the presence of caries lesions, so risk identification and screening accuracy may focus on the same indicator. Other risk indicators for early childhood caries are available from observational, demographic and health history data, but they remain untested. Of course, if the object of risk assessment is to prevent any incidence of caries, these risk indicators assume additional importance, as the presence of 1 or more lesions represents both an indication of elevated risk and a failure of prevention. Not only are there no studies examining the predictive validity of PCC classifications of children based on these risk indicators, there are also no studies of how accurately PCCs can identify the presence of these indicators in preschool children.

## Referral Effectiveness

The evidence assessing the effectiveness of PCC referral for dental care is poor. We identified only 1 study pertinent to the key question, and it had internal validity problems. This study, as well as a study excluded because a home visitor made the referral, suggests that PCC referral may be only partially effective.

## Effectiveness of Fluoride Supplementation

### Appropriateness of Supplementation Decision

The strength of the evidence assessing the appropriateness of PCC's prescription of supplemental fluoride is fair principally because of its consistency. The studies in this evidence base are primarily self-report, have relatively low response rates, were conducted chiefly in the 1980s when dosing recommendations were different, and address general behaviors and knowledge more than specific patient-based decisions. Thus, most studies have both internal and external validity problems.

The studies indicate that the majority of physicians and the large majority of pediatricians do prescribe fluoride supplements to at least some of their patients. However, not all physicians report that they know the fluoride status or the specific fluoridation level of their patients' water supplies. This finding suggests that inappropriate prescribing is possible because fluoride availability is a key component in the decision to prescribe supplements.

Further, respondents' performance on tests of knowledge of appropriate prescribing behaviors ranged from 42% to 91%, generally indicating a knowledge deficit that tended to be smaller among pediatricians than among family and other physicians. The 2 patient-based assessments of appropriateness support the self-report findings. Physicians, residents, and medical students made imperfect supplementation decisions after educational interventions designed to improve those decisions.

Although they must be considered as indirect evidence, the results concerning physicians' knowledge of fluoridation status of their patients do represent the only information available describing physicians' accuracy in assessing risk for dental caries. The results suggest that, at least for this risk factor, physicians do not achieve high levels of accuracy, principally because the information necessary for risk assessment is not collected.

### Parental Adherence

The strength of the evidence for PCC effectiveness in securing parental adherence to daily supplementation regimens is poor. We found no studies examining this question. Available formal studies of parental adherence suggest that it is poor, with the dropout rate largest early in the course of supplementation.

### Effectiveness of Supplements

The strength of the evidence concerning the effectiveness of fluoride supplementation is fair, chiefly owing to its consistency. The available clinical trials are generally of fair to poor quality, typically using convenience samples without random assignment. None of the studies used an intent-to-treat analysis; in most studies, subjects were excluded from the analyses for nonadherence. Dropout rates, when noted, were high, and measurement reliability generally was not assessed. External validity is also an issue, with 4 studies completed in the 1970s and the more recent trials performed in China and Taiwan. The studies were consistent, indicating that among those who comply with supplementation schedules, supplementation is effective in preventing 30% to 80% of caries lesions in primary teeth, with NNTs ranging from 0.6 to 2.6.

A smaller body of evidence points to effectiveness with respect to permanent teeth when supplements are initiated in preschool children. These 2 studies are supported by a larger body of evidence (not reviewed here) examining the effectiveness of supplementation on permanent teeth when initiated in school-aged children. ^69^

A recommendation on the use of fluoride supplements during the first 5 years of life must consider the risks of dental caries, the effectiveness of supplements in preventing dental caries, and the potential for harms. Dental caries does not affect the majority of preschool children. By 5 years of age, about 40% of children are affected, and its presence is highly dependent on the socioeconomic circumstances of the family.

Moreover, the prevalence and severity of fluorosis has increased since baseline measures for water fluoridation were assessed in the 1940s. Limited evidence suggests that the public can discern changes in tooth color due to fluorosis. Cases of objectionable fluorosis can be attributed primarily to inappropriate use of fluoride, such as early use of too much fluoridated dentifrice, preparing infant formula with fluoridated water, or inappropriate use of supplements in fluoridated communities. The evidence regarding a cause-and-effect association between use of supplements in communities with fluoride-deficient drinking water and elevated risk for fluorosis is strong. One study suggests that two-thirds of moderate fluorosis in nonfluoridated areas is attributable to supplement use, albeit based on dosages no longer recommended. ^76^

Dental caries remains a major public health problem for the poor and those without adequate access to dental care. Fluoride therapy is important in the prevention and control of this disease for this segment of the population as well as the population in general. However, a number of uncertainties exist concerning the importance of dietary fluoride supplements in caries prevention for US populations. The USPSTF has rated the evidence for effectiveness of supplements in preventing caries in the primary dentition as fair, and only 2 studies have been conducted of caries in permanent teeth when supplementation was started before 5 years of age. Limited research has been done on the public's perceptions of enamel fluorosis in the United States, and no studies have been conducted with the general population according to socio-economic status, which has a major effect on caries experience. Likewise, there are no studies of the caries preventive effects of supplements using the 1994 dosage schedule or the amount of fluorosis that might occur.

Expert panels have twice considered the tradeoff between caries prevention and fluorosis since the dosage schedule for dietary fluoride supplements was first developed. Each time the deliberations resulted in a reduction in the dosage schedule. The most recent change occurred in 1994: initial supplementation was delayed to 6 months of age, and the dosage was reduced for children younger than 6 years, the ages when enamel of most permanent teeth is at risk for fluorosis. No studies have assessed the effect of these changes on dental caries or fluorosis prevalence.

CDC guidelines on fluoride use concluded that children and adults who have low risk for caries are able to maintain their oral health through frequent exposures to small amounts of fluoride, notably drinking fluoridated water and use of fluoridated toothpaste. About one-third of the US population does not have access to drinking water that is fluoridated, a fundamental intervention for the prevention and control of dental caries. Thus, a large percentage of US children still can be considered for fluoride supplementation, which is intended to mimic the caries-inhibiting effects of water fluoridation. Residence in a nonfluoridated community should be one of the considerations for risk determinations. However, large numbers of children in nonfluoridated communities are caries free or have small numbers of affected teeth, which suggests that fluoridation alone is not the only risk factor to be considered in this complex disease.

Both ADA and CDC guidelines suggest that supplements be used judiciously and be reserved for children who are at elevated risk for caries regardless of the fluoridation status of their drinking water; AAP has endorsed the CDC guidelines on fluoride use. This approach to fluoride supplementation acknowledges that the risk of fluorosis might outweigh the benefits of caries reductions in those children who have low risk for disease.

## Effectiveness of Fluoride Application

### Appropriateness of Application Decision

Adoption of fluoride varnish by primary care providers is in its early stages in the United States. Its use in dentistry is common practice in Europe. Information on the extent to which fluoride varnish is used in dental practice in the United States is limited, but anecdotal information suggests that it might be increasing. Some dental schools are teaching its use, the number of products available on the market has increased from one when it was first approved by the FDA to four, and insurance companies are promoting its use. Use of fluoride varnish by general dentists increased from 32% to 44% in Washington State after it was promoted as a dental benefit. ^92^ The primary incentives for its use over other topical fluoride agents are its ease of use, patient acceptance, and reduced potential for toxicity.

Information on use of fluoride varnish by physicians or other primary health care providers is even more limited than for the dental profession. A few states provide reimbursement to physicians through their Medicaid programs, but service statistics are generally unavailable. ^93^ A national study supports the early stages of exposure of physicians to this intervention. Only 22% of pediatricians reported that they were familiar with fluoride varnish. ^78^

### Parental Agreement

No information is available on parental acceptance of a PCC's recommendation to have a topical fluoride application for their child. Likewise, no evidence of concern or refusals has been reported in the literature.

### Effectiveness of Fluoride Application

The evidence supporting the effectiveness of fluoride varnish in the prevention of dental caries in preschool-aged children is fair. No studies are available beginning at 1 or 2 years of age (i.e., the time that children at high risk for dental caries need to begin treatment), but results of clinical trials of older children are consistent.

Six trials have tested the caries-inhibiting effects of fluoride varnish when applied to primary teeth of children younger than 6 years of age. The quality of these studies is generally good. Four studies, including all 3 RCTs, showed caries-inhibiting effects. In 1 of the 2 studies with nonsignificant differences, Grodzka et al. used group assignment of children attending education centers and were unable to control adequately for potential group differences. ^94^ Petersson et al. studied Swedish clinic patients with low caries rates. ^95^ Fluor Protector® had no effect overall but did have statistically significant caries-inhibiting effects for children with high rates of decay on interproximal tooth surfaces, which presumably places these children in a high-risk category.

The RCT by Holm provides the strongest evidence of a caries-preventive effect. ^96^ Children were followed for 2 years, with a caries reduction of 43.8% and an NNT of 1.2. The other 2 RCTs with positive effects are either of short duration ^80^ or embed the evaluation of Duraphat® in a selected population derived from an intervention study of invert sugar. ^97^ The Duraphat®-only group resulted from random assignment of those who did not want to participate in the sugar trial to the treatment and control groups. These studies of fluoride varnish use in young children are supported by a larger body of evidence that provides good evidence of effectiveness in permanent teeth for topical applications of both fluoride varnish ^98,^ ^99^ and other fluoride compounds. ^100,^ ^101^

## Effectiveness of Counseling

### Adherence to Recommendations and Caries Prevention

The USPSTF found insufficient evidence for the effectiveness of counseling provided by PCCs for caries-preventive behaviors. The single available study describes an ineffective intervention.

The systematic reviews of the oral health promotion and dental health education literature suggest that knowledge improvement is easily achieved but that behavioral change is more difficult. They also suggest that caries reduction is likely only if the behavioral change involves use of fluoride. The 3 studies of counseling parents of infants describe oral hygiene behavior and caries reduction results that are more promising than what the entire literature would suggest, as noted in Table 9. These three interventions all featured individual, personalized contact, which the reviews suggested is more effective in achieving behavioral change than more impersonal methods. Also, the personnel involved in the interventions were either dental auxiliary personnel (dental hygienists, dental assistants) or dental health educators.

### Other Issues: Pediatric Medications Containing Sugar

In the course of completing the reviews required to address the key questions, we encountered an additional aspect of dental health among children that may involve primary care providers. Many pediatric medicines contain sugar, presumably to make them more palatable. The extent to which long-term use of these medicines affects oral health is at issue. The strongest evidence available comes from 2 cross-sectional comparisons of children with histories of long-term (6 or more months) use of sugar-sweetened liquid medication with controls matched on age and, in 1 study, race, sex, number of teeth, fluoridation history, and dentist. ^102,^ ^103^ One study, which was conducted in a nonfluoridated area using visual examination techniques only, included 44 children in the exposure group and 47 controls. Mean primary tooth caries experience was 4.4 times as great in the exposure group (defs = 5.55) as in the controls (defs = 1.26). The other study was conducted in a fluoridated area, used radiographs as a part of the examination, and included 40 children in both the exposure and control groups. Mean caries experience was 2.9 times as great in the exposure group (defs = 4.57) as in the controls (defs = 1.55). Although these studies were unable to control for all possible risk factors, their results should be considered at least suggestive of the oral health risk associated with the long-term use of sucrose-sweetened medications among preschool children.

### A Research Agenda

The evidence base for recommendations to physicians concerning dental caries prevention in young children needs to be strengthened. A key issue that underlies many of the possible preventive initiatives available to physicians and other primary care clinicians is whether they can accurately assess risk of dental caries. Elements of this issue include the predictive validity of current risk indicators and physicians' application of these indicators. Not all of the risk indicators currently advocated for use (Table 4) have been validated individually in prospective studies, and the relative strength of combinations of these indicators is entirely untested. Thus, echoing the recommendation of the recent NIH Consensus Development Conference on Diagnosis and Management of Dental Caries Throughout Life, ^104^ “more and higher-quality comprehensive, longitudinal, multifactor studies of implicated risk indicators are needed to obtain firm support for their associations with caries incidence, to clarify the strengths of these associations in differing populations, and to reveal the extent to which the indicators provide independent as opposed to redundant information.” In addition, assessments of the accuracy of physicians' use of these risk indicators in identifying young children at elevated risk for dental caries are needed.

Several other issues also merit additional examination. One is the effectiveness of PCC application of fluoride varnish for delaying the initial onset and reducing the incidence and increment of dental caries in young children. The existing studies constitute only fair evidence, represent efficacy studies, and were all performed by dental personnel. One or more effectiveness studies performed under field conditions by PCCs would strengthen the evidence base for this incompletely evaluated approach to prevention.

A second issue that could benefit from additional studies is the effectiveness and adverse outcomes of the current dosing schedule for supplemental fluoride. As noted, the recommended dose has been reduced twice in little more than a decade, and no studies of the effects of the most recently recommended regimen have been reported. Studies should examine preventive effectiveness and also quantify risk of fluorosis by severity.

Another issue for which further study is recommended is already the focus of increasing interest, and the results of ongoing studies may have substantial implications for counseling pregnant women and new mothers in the future. Efforts to block or delay the transmission of cariogenic bacteria from caregiver to child should be evaluated for their long-term effectiveness as well as their effectiveness in the short term. Even if the outcome of such efforts is simply to delay the appearance of lesions among the most susceptible, such a delay would increase the likelihood of exposure to other preventive interventions before the time that the development of a child's first lesion could be expected, which presumably could have an effect on caries incidence. The investigations into this potential approach to prevention should be broadened to include additional populations and investigators.

Obviously, the effectiveness of PCC counseling for behaviors to promote oral health needs to be examined. Given the little that is known about effectiveness, the greater amount of effort should be placed on developing approaches to increase current levels of effectiveness, rather than simply documenting these levels. Much of the arsenal of preventive interventions available to PCCs depends on parental compliance with counseled behaviors, and methods to increase compliance need to be explored.