# Results

Table 1 summarizes the results of the searches for studies involving PCCs. It shows (a) the number of studies initially identified by the search, (b) the number of additional studies identified through other sources, (c) the number of these studies that either of 2 reviewers targeted for detailed review, and (d) the number found to address the key question irrespective of the research design employed by the study. Table 2 summarizes the sources of collateral evidence for effectiveness from the dental literature for 3 key questions.

Table 1 Search Results on Studies of Primary Care Providers' Involvement in Child Oral Health

| Key Question | Identified in MEDLINE Search | Added from Other Sources | Reviewed in Detail | Included
1 | Screening accuracy | 117 | 1 | 12 | 2
2 | Referral effectiveness | 102 | 0 | 12 | 1
3–4 | Fluoride supplementation and fluoride application | 31 | 7 | 17 | 12
5 | Counseling for caries preventive behaviors | 137 | 3 | 20 | 1

Table 2 Sources of Data for Collateral Evidence from the Dental Literature

| Key Question | Published Reviews | | New Review | Updated Review
| | Systematic | Narrative
3 | Fluoride supplementation | 1 | 4 | 1 | 0
4 | Fluoride application | 1 | 0 | 0 | 1
5 | Counseling for caries preventive behaviors | 4 | 0 | 0 | 0

## Accuracy of Screening by Primary Care Clinicians

### Identifying Needed Referrals

We considered screening to consist of visual oral examination and parental interview. We searched only for reports involving accuracy of the visual examination in identifying treatment needs requiring referral to a dentist.

We found 2 studies germane to the visual oral examination component of PCC screening accuracy among children; both reported the performance of a single PCC visual screener, a nurse and a pediatrician (Table 3). ^41,^ ^42^ The pediatrician identified presence or absence of “nursing caries,” i.e., a caries lesion on any teeth other than mandibular incisors through examination with a mirror among children 18 to 36 months of age. No criteria for visual recognition of caries were reported, and 4 hours of training were provided. The comparison standard was a similar screening by a pediatric dentist. The nurse identified presence or absence of caries lesions, restorations, fluorosis, intraoral injuries, sealants, and urgent and nonurgent treatment needs among children 5 to 12 years of age using a flashlight and tongue blade. Caries lesions were to be noted only if cavitation (loss of surface continuity) was present. Five hours of training preceded the assessment. The comparison standard was a visual-tactile screening examination by a dentist.

Table 3 Studies Reporting Screening Accuracy for Primary Care Providers

Citation | Condition To Be Detected | Population Screened | Population Prevalence | PCC Screener | Training | Comparison Standard | Sensitivity/Specificity
Serwint et al, 1993 ^41^ | Untreated decay anywhere but lower primary incisors | Children 18 to 36 months, n = 61 | 20% | Pediatrician, n = 1 | 4 hours | Pediatric dentist | Sens = 100%
| | | | No prior dental experience | | | Spec = 87%
Beltran et al, 1997 ^42^ | Untreated decay in primary and permanent teeth | Children 5 to 12 years, n = 219 | 35.2% | Nurse, n = 1 | 5 hours | Dentist | Sens = 92.2%
| | | | No prior dental experience | | | Spec = 99.3%
| Restorations | n = 233 | 39.9% | | | | Sens = 96.7%
| | | | | | | Spec = 99.3%
| Fluorosis | n = 323 | 40.3% | | | | Sens = 72.3%
| | | | | | | Spec = 96.4%
| Injuries | n = 323 | 12.1% | | | | Sens = 79.5%
| | | | | | | Spec = 97.5%
| Sealants | n = 323 | 6.8% | | | | Sens = 59.1%
| | | | | | | Spec = 99.7%
| Nonurgent treatment | n = 288 | 18.4% | | | | Sens = 66.0%
| | | | | | | Spec = 99.2%
| Urgent treatment | n = 261 | 10.7% | | | | Sens = 100%
| | | | | | | Spec = 100%

Note: PCC, primary care clinician; sens, sensitivity; spec, specificity.

In both studies, the clinicians achieved high levels of screening accuracy (sensitivity and specificity) for dental caries following training. Sensitivities were 100% and 92% and specificities were 87% and 99% for the pediatrician (20% prevalence) and nurse (35% prevalence), respectively. ^41,^ ^42^ The nurse performed similarly in identifying children with restorations but was less accurate in identifying fluorosis, injuries, sealants, and nonurgent treatment. Many of the children in this study were older than 5 years, which may have reduced behavioral problems, thereby improving examination conditions.

### Identifying Elevated Risk for Caries

Although formal risk categorization is infrequent in current dental practice, its use has been encouraged. ^43,^ ^44^ The number of risk indicators for dental caries is large, ^18,^ ^28^ and subsets of these indicators are frequently suggested for use in dental practice. Table 4 lists risk indicators identified in 2 widely distributed sources, the Bright Futures project from the Health Resources and Services Administration (HRSA)34 and the Journal of the American Dental Association's special supplement on caries diagnosis and risk assessment. ^23^

Table 4 Risk Indicators for Dental Caries in Children Suggested for Use in Dental Practice*

Clinical Indicators
One or more caries lesions
Caries lesion restored within the past year
Deep pits and/or grooves on tooth surfaces
Plaque retention
White spots on smooth surfaces
Elevated S mutans level
Low salivary flow
Behavioral Indicators
Frequent between-meal sugar intake
Special carbohydrate diet
Inappropriate baby bottle use
Irregular brushing
Eating disorders
Long-term use of sugared medications
Socio-environmental Indicators
Inadequate fluoride (nonfluoridated water supply or use of bottled or filtered water)
Caries in siblings, parents, or both
Lower socioeconomic status

* Adapted from Bright Futures in Practice: Oral Health ^34^ and the American Dental Association. ^23^

The clinical risk indicators most accessible for PCC to use in screening preschool children are the presence of caries lesions, plaque retention, and the presence of white spots or other evidence of demineralization, such as discolored pits and fissures of teeth. PCCs might ascertain several of the socio-environmental and behavior indicators by interview or questionnaire, and they may already be available through health history and behavioral data that are routinely collected. Nevertheless, we found no studies that examined PCC accuracy in identifying children who displayed one or more risk indicators using these or other risk indicators, with the exception of the studies summarized under key question 3a, which examine the appropriateness of PCC's decisions regarding fluoride supplements.

### Effectiveness of Primary Care Clinician Referral to a Dentist

A single case study reported on the effectiveness of PCC referral (Key Question No. 2). ^45^ The study (Table 5) examined the effectiveness of referrals to dentists made by health professional assistants for the Women, Infants and Children (WIC) Supplemental Food Program for eligible children ages 6 months to 5 years. Children who were referred on the basis of non-normal findings during intraoral screening examinations were almost twice as likely to have made a dental visit in their lifetime than children who were not referred, 37% compared to 19%. The study did not control for time elapsed since the referral had been made, and the difference in the visit rates was not significant when controlled in a multivariate analysis for child age, maternal age, household size, presence of dental insurance, and mother's perception of the child's dental needs. We did not examine collateral evidence in the dental literature for this question because no parallel situation exists.

Table 5 Studies Reporting Referral Effectiveness

Citation | Population | Percent Referred | Reason For Referral | Referrer | Percent With Dental Visit
McCunniff et al., 1998 ^45^ | WIC participants, 6 months to 5 years | 33% | Any abnormality found at screening | Health professional assistant | Referred = 37%
| n = 269 | | | | Not referred = 19%
| | | | | P = < 0.05*

Note: WIC, Women, Infant and Children program.

* Statistically significant in bivariate analysis; not significant in multivariate analysis controlling for age, maternal age, household size, dental insurance, mother's perceptions of child's dental needs.

A study that did not meet the inclusion requirement of patient contact in an office or clinic environment reported still less effective results. ^46^ When health visitors in England referred children ages birth to 2 years to dentists for dental examinations, 21% of those referred actually visited a dentist.

### Effectiveness of Fluoride Supplementation

#### Appropriateness of Supplementation Decision

We identified 12 studies that addressed the appropriateness of PCCs' prescription of supplemental fluorides; of these, 10 were surveys of physicians' knowledge and behavior concerning fluoride supplementation (Table 6). ^47^ – ^56^ These studies offer only indirect evidence concerning the appropriateness of fluoride supplementation in young children because they constitute self-reported physician data and do not assess prescribing behaviors for individual children. The survey items are too dissimilar and the results too heterogeneous to permit quantitative synthesis.

Table 6 Physicians' Knowledge of and Behavior Regarding Fluoride Supplementation

Citation | Response Rate, Number of Subjects | Venue, Percent with Optimal Fluoride | Type of Physician | Prescribe Fluoride to Any Patients | Know Fluoride Level Status | Mean of Appropriate Responses, N Items
Margolis et al.,1980 ^47^ | 49% | National, Varies | Pediatr | 81% | 96%* | 79%, 3
| 1,286 | | Fam | 63% | 74%* | 68%, 3
Siegel and Gutgesell, 1982 ^48^ | 56% | Houston Suboptimal | Pediatr | 48%r^†^ | 69%^‡^ | 75%, 1
| 238 | | Fam | 18%r^†^ | 26%^‡^ | 42%, 1
Gift et al., 1984 ^49^ | 50% | National, Varies | All Active in Child Care | 80% | NR | 78%, 6
| 933
Rigilano et al.,1985 ^50^ | 47% | Air Force, Varies | Pediatr | NR | 74%^‡^ | 87%, 4
| 237 | | Fam and OB | NR | 58%^‡^ | 64%, 4
Levy, 1987 ^51^ | 77% | Acad. HC, Unknown | Fam (fac, res, affil) | ~80% | 67% | NR
| 37
Kuthy and McTigue,1987 ^52^ | 60% | Ohio, Varies | Pediatr | 86% | 91% | NR
| 1,332 | | Fam | 73% | 83% | NR
Margolis et al.,1987 ^53^ | 45% | National, Varies | Pediatr | 90% | 97%* | 91%, 3
| 1,269 | | Fam | 76% | 86%* | 91%, 3
Dillenberg et al., 1992 ^54^ | 31% | Arizona, Suboptimal | Pediatr | 70% | NR | 53%, 4
| 280 | | Other | 47% | NR | 32%, 4
Jones and Berg, 1992 ^55^ | 62% | Houston, Suboptimal | Pediatr | 97% | NR | 49%, 1
| 95
Roberts et al.,1998 ^56^ | 95% | Acad HC, Unknown | Pediatr | 93% | NR | 79%, 2
| 40

Note: subopt, suboptimal; acad HC, academic health center; pediatr, pediatrician; fam, family physician; OB, obstetrician, fac, faculty; res, resident; affil, affiliated; NR, not reported.

* Percentage of patients with municipally fluoridated water

† Prescribe routinely ( r )

‡ Fluoride concentration of water in practice area

§ Approximate percentage of patients with fluoridated water

¶ Routinely addressed needs

Although survey results vary considerably, in general a large proportion (more than 75%) of pediatricians and a lesser proportion of family practitioners have reported providing supplemental fluoride to at least some of their child patients. Individual questions in some of the surveys indicated, however, that at the community and individual levels, physicians were not perfectly informed about local fluoridation status, which may lead to inappropriate supplementation decisions. In 2 studies, ^48,^ ^50^ only 69% and 74% of pediatricians and 26% and 58% of family practitioners reported knowing the fluoridation status of their practice areas. Only small proportions of physicians ever reported using water sample analyses to determine fluoride levels for individual water supplies. ^51,^ ^52,^ ^54,^ ^55^ In another study, 56% and 71% of physicians practicing in large and smaller fluoridated cities, respectively, reported prescribing supplements, signaling possible inappropriate supplementation. ^53^ Finally, in 1 study, 15% of family physicians and 9% of pediatricians indicated making no inquiries about fluoridation status before prescribing fluoride supplements. ^52^

Further, physicians' age-specific dosage recommendations were often different from recommendations from the AAPD or the ADA. The right-most column in Table 6 summarizes the percentage of appropriate responses to survey items regarding age-specific dosage and recommended prescribing procedures. Pediatricians tended to answer appropriately more often than other physicians. Apart from the differences evident in the 2 surveys by Margolis and colleagues (in 1980 and 1987), ^47,^ ^53^ we could see no indications that physician knowledge has improved in the past two decades. Similarly, no obvious change has occurred in the proportion of physicians who prescribe fluoride supplements to at least some of their patients.

Two patient-based assessments of appropriate management of fluoride supplementation have been reported. ^57,^ ^58^ Twenty family medicine residents improved their knowledge of systemic fluoride therapy following a videotape presentation, but the percentage of patients appropriately managed did not change, remaining around 60%. In contrast, 88% of children visiting a single family health center were managed appropriately immediately following the institution of a new protocol. The pre-protocol level of appropriate management was estimated to have been no more than 25%. Primary care providers in the study were 2 family physicians, 1 physician assistant, and an unknown number of medical students. This study did not follow up to determine whether appropriate management was maintained at the higher post-protocol level over the longer term.

#### Parental Adherence

We found no eligible studies of PCC effectiveness in terms of the level of parental adherence achieved with the daily dosage regimen. Our review of the dental literature similarly found no studies of effectiveness of dentists with respect to gaining parental adherence.

Indirect evidence is available for this question from adherence information collected during some supplement trials and from studies of population cohorts. Based on recent parental estimates, among Iowa infants receiving supplements at any time in the first 12 months, the mean daily dose over the full year was 0.07 mg, far less than the recommended 0.25 mg. ^59^ Parental adherence in providing supplements for Swedish preschool children had been no better two decades earlier. ^60^ Parental reports indicated that 51% of children had received supplements at some time during ages 6 months to 7 years; 12% had taken supplements regularly for a minimum of 5.5 years. Similarly, among Australian children who began receiving supplements early in life, only 18% received them regularly by age 5 to 6 years. ^61^ In a group of Canadian children 3 to 9 years old, of 35% reported to be using supplements at a certain point, 58% had discontinued their use within 1 year. ^62^

#### Prevention of Dental Caries

Tables 7A and 7B summarize 6 trials of the effectiveness of fluoride supplements in preventing dental caries in primary teeth when the supplementation was initiated before the age of 5 years. ^63^ – ^68^ These studies represent a variety of designs in terms of age at first use of fluoride, dosage, background fluoride level, duration of the trial, and assignment method (Table 7A).

Table 7A Effects of Fluoride Supplements on Primary Teeth: Study Design Characteristics

Citation | Site and Background Fluoride Level | Base-line Number of Subjects and Age | Experimental Intervention | Control Intervention | Assignment Method | Population Description | Blinding | Number of Examiners | Examiner Agreement | Exam Criteria
Hamberg, 1971 ^63^ | Sweden | 705 | 0.5 mg F and V drops | V drops | Unclear: possibly random | Visitors to well-baby clinics | Parents and examiners | 1 | NR | NR
| ~0.2 ppm | 2–3 weeks
Hennon et al, 1972 ^64^ | Indiana | 815 | E_1_: 1.0 mg | V chews | Unclear: stratified by age, caries | Unknown source | Parents; presumably examiners | NR | NR | ADA 1966 and bitewings
| <0.4 ppm, some with >exposure | 18–39 months | F chews
| | | E_2_: 1.0 mg
| | | F and V chews
Margolis et al, 1967, ^105^ 1975* ^65^ | Michigan and New York nonfluoridated | 297 | 0–3 yr: 0.5mg | 0–3 yr: | Unclear: may not be from same population | Infants in pediatric offices | Parents and examiners | Multiple, number not reported | NR | NR
| | 1–4 months | F and V drops | V drops
| | | 3+ yr: 1.0 mg | 3+ yr:
| | | F and V chews | V chews
Hennon et al, 1977 ^66^ | Indiana | 456 | 0–3 yr: 0.5 mg | 0–3 yr: | Systematic: stratified by age, sex | Infants in 8 towns with in-range F levels | Parents and examiner | 1 | NR | NR, bitewings used
| 0.6–0.8 ppm | 1–14 months | F and V drops | V drops
| | | E_1_ 3+ yr: 1.0 mg | 3+ yr:
| | | F and V chews | V chews
| | | E_2_ 3+ yr: 0.5 mg
| | | F and V chews
Hu et al, 1998 ^67^ | China | 324 | 2 yr: 0.25 mg | None | Unclear, all similar SES: assigned by school | Kindergarten students | NR | 2 | r = 0.90 | Radike
| <0.3 ppm | 24 months | F drops
| | | 3+ yr: 0.5 mg
| | | F drops
Lin and Tsai, 2000 ^68^ | Taiwan | 140^†^ | E_1_: 0.25 mg | None | Random | Patients at cleft clinic | Examiners | 2 | k = 0.85 | WHO
| <0.1 ppm | 22–26 months | F chews
| | | E_2_: 0.25 mg
| | | F drops

Note: ppm, parts per million; wk, weeks; mo, months; yr, year; E_1_, experimental group 1; E_2_, experimental group 2; F, fluoride; V, vitamins; chews, chewable tablets; SES, socioeconomic status; NR, not reported; ADA, American Dental Association; WHO, World Health Organization.

Table 7B Effects of Fluoride Supplements on Primary Teeth: Study Results

| Baseline (SD) | | Exp Time | Increment (SD) | | Percentage Reduction | | NNT | | Drop-out (%) | Compliance Addressed
| deft | defs | | deft | defs | deft | defs | deft | defs
Hamberg, 1971 ^63^ | C | C | 6 yr | C | NR | | NR | | NR | NR | No
| 0 | 0 | | 5.2 (NR)
| E | E | | E^‡^
| 0 | 0 | | 2.7 (NR) | | 48% | | 2.4
Hennon et al, 1972 ^64^ | C | C | 2 yr | C | C | | | | | 65% | No
| 0.5(0.1) | 0.5(0.1) | | 4.5 (0.4) | 6.9 (0.9)
| E_1_ | E_1_ | | E_1_ | E_1_
| 1.2(0.3) | 2.0(0.7) | | 1.4 (0.3) | 2.4 (0.5) | 69% | 65% | 0.6 | 0.4
| E_2_ | E_2_ | | E_2_ | E_2_
| 0.8(0.2) | 1.0(0.2) | | 2.0 (0.3) | 2.6 (0.4) | 56% | 62% | 0.8 | 0.5
Margolis et al, 1967, ^105^ 1975 ^65^ | C | NR | 6 yrs | C* | NR | | NR | | NR | NR | No
| assumed 0 | | | 2.2 (0.2)
| E | | | E* | | 68% | | 1.3
| assumed 0 | | | 0.7 (0.1)
Hennon et al, 1977 ^66^ | C | C | 5 yrs | C | C | | | | | 71% | No
| assumed 0 | assumed 0 | | 6.0 (0.6) | 8.7 (1.1)
| E_1_ | E_1_ | | E_1_ ^#^ | E_1_ ^#^
| assumed 0 | assumed 0 | | 3.5 (0.5) | 4.6 (0.7) | 42% | 47% | 2.0 | 1.2
| E_2_ | E_2_ | | E_2_ ^#^ | E_2_ ^#^
| assumed 0 | assumed 0 | | 4.1 (0.4) | 5.4 (0.8) | 32% | 38% | 2.6 | 1.5
Hu et al, 1998 ^67^ | C | C | 3 yrs. | C | C | | | | | 26% | School based, exclude if <180 days of receipt
| 0.4 (0.1) | 0.6 (0.10) | | 3.9 (NR) | 6.9 (NR)
| E | E | | E^#^ | E^#^
| 0.5 (0.1) | 0.6 (0.1) | | 1.8 (NR) | 3.4 (NR) | 54% | 51% | 1.4 | 0.9
Lin and Tsai, 2000 ^68^ | C | C | 2 yrs | C | C | | | | | 18% | Interview and check of use. Exclusion if >11% of materials not used.
| 0.3 (0.1) | 0.3 (0.1) | | 4.2 (0.8) | 8.4 (2.1)
| E_1_ | E_1_ | | E_1_** | E_1_
| 0.4 (0.1) | 0.4 (0.1) | | 2.0 (0.4) | 4.1 (1.0) | 52% | 51% | 0.9 | 0.5
| E_2_ | E_2_ | | E_2_ | E_2_
| 0.2 (0.1) | 0.2 (0.1) | | 1.2 (0.3) | 1.6 (0.5) | 72% | 81% | 0.7 | 0.3

Note: deft/s, decayed, identified for extraction, filled primary teeth/surfaces; C, control group; E, experimental group; E_1_, experimental group 1; E_2_, experimental group 2; SD, standard deviation; NNT, number needed to treat; NR, not reported; F, fluoride

* Data from 2 parallel studies combined in this table.

† Children with cleft lip and/or palate.

‡ No statistical testing reported.

§ Different from control at P < 0.001.

║ Increment from age 4–6 only (2 year increment).

¶ Different from control at P < 0.005.

# Different from control at P < 0.05.

** Different from control at P < 0.01.

Across these differences, reductions in the number of both teeth and tooth surfaces with caries lesions were consistently associated with use of supplements (Table 7B). The ranges of percentage reductions were 32% to 72% for primary teeth and 38% to 81% for primary tooth surfaces. The smallest proportional reductions occurred in the study with the highest background fluoride level, a level that is not considered appropriate for supplementation under current guidelines. ^25^ All reported statistical tests were significant.

These studies indicate that fluoride supplementation is effective in preventing dental caries; numbers needed to treat (NNTs) to prevent 1 additional carious tooth surface over 1 year ranged from 0.3 to 1.5. Nontheless, generalization of these results must be done cautiously. Dropout rates in 2 studies were high (approximately two-thirds of the original samples); the dropout rate could not be determined in 2 studies. Two other studies with lower dropout rates involved a school-based program and a Taiwanese study of cleft palate children, where parental motivation may have been high because of both societal norms and other childcare requirements. No study used an intent-to-treat analysis. Equally as problematic, assignment method could not be determined in 4 studies.

Not shown in Table 7 are data about caries reductions for permanent teeth associated with use of fluoride supplements initiated before age five. Two such studies met our inclusion criteria; both are extensions of studies described in Table 7. Margolis et al reported total permanent tooth caries increments at ages 7 to 10 years for children taking fluoride supplements since age 1 to 4 months. ^65^ Compared to controls, the total number of permanent teeth experiencing caries was reduced 58% and 33% in 2 communities. The latter reduction was not statistically significant; only 28 intervention group children were available for examination in this community. Hamberg reported a 70% to 80% reduction in caries increments at age 7 to 8 years among first molars in the supplement group compared to controls but gave no statistical testing information. ^63^ These reductions mirror the wide range of statistically significant reductions in caries experienced in permanent teeth when supplementation has been started later, as a part of a school-based program. ^69^

#### Enamel Fluorosis

Enamel fluorosis is the only harm that can result from the use of dietary fluoride supplements and that is only of aesthetic importance. ^70,^ ^71^ This condition is characterized by a continuum of changes in the enamel that result from increasing degrees of hypomineralization. The very mild forms of fluorosis appear as chalklike, lacy markings across a tooth's enamel surface. Most often these slight changes are visible only when the enamel is dried and viewed under direct and careful observation. As the severity of fluorosis increases, larger areas of the enamel surface are affected and it can be observed during normal day-to-day personal interactions. The threshold at which fluorosis generally is thought to be noticeable by the public is when more than one-fourth of the enamel surface of a visible tooth is affected with a change in color from its normal, glossy creamy white appearance to an opaque-white appearance (mild or greater according to Dean's criteria). ^71^

The prevalence of fluorosis has increased during the last 50 years. ^72^ – ^75^ The only national survey of fluorosis in the United States found a prevalence of 23.5% for permanent teeth in children 5 to 17 years of age (13.5% in children attending schools with < 0.3 ppm F; 21.7% with 0.3 to 0.7 ppm F; 29.9% with 0.7 to 1.2 ppm F). ^74^ Almost all cases were of the very mild form. About 13.1% of children who were continuous residents of nonfluoridated communities had very mild fluorosis; the figure was 28.3% in fluoridated communities. The prevalence of cases in children considered to be of some aesthetic consequence by dental professionals or the public is between 3% and 7%.

Dietary fluoride supplements are a primary risk factor for fluorosis. ^40^ A recent systematic review examined individuals' risk of enamel fluorosis resulting from the regular use of fluoride supplements in nonfluoridated communities among children birth to 6 years of age. ^40^ The review included 10 cross-sectional studies that depended on parental recall to identify extent of exposure to supplements and 4 follow-up studies in which supplement use had been recorded earlier and outcomes were determined via subsequent clinical examinations.

In general, the dosage(s) used in these studies exceeded current recommendations. Prevalence of fluorosis associated with regular use ranged from 10% to 49% in the cross-sectional studies; incidence ranged from 15% (on central incisors only) to 67% in the follow-up studies. The cross-sectional studies identified odds ratios of dental fluorosis associated with regular use during the early years of life ranging from 1.3 to 10.7. Meta-analyses using 3 different approaches (Mantel-Haenszel, generalized variance, DerSimonian-Laird) gave summary odds ratios of 2.6, 2.6, and 2.4; the widest 95% confidence interval (CI) was 1.7 to 4.1. For the follow-up studies, individual relative risks ranged from 4.2 to 15.6; summary relative risks derived using the three meta-analytic approaches were 12.2 (95% CI, 4.9–30.4), 5.6 (95% CI, 3.4–9.4), and 5.5 (95% CI, 2.7–11.4).

The review concluded that use of fluoride supplements increases the risk of developing dental fluorosis, even though the condition is very mild in the large majority of children. No analysis of the proportion of all children experiencing fluorosis who will experience more severe forms was presented, largely because the original studies did not report these data.

Pendrys has calculated attributable risk estimates for dietary fluoride supplements for middle school children living in several communities in Massachusetts and Connecticut. ^76^ After adjusting for a several other fluoride sources, nearly two-thirds of the cases of mild-to-moderate enamel fluorosis (i.e., greater than 50% of at least 2 tooth surfaces as defined by the Fluorosis Risk Index having paper-white streaking, coalescences to opacities, or both) observed in nonfluoridated areas (prevalence of 39%) could be attributed to the use of supplements with the pre-1994 dosage schedule. The other one-third of cases could be attributed to the early use of fluoride toothpaste. As many as 13% of cases in fluoridated communities (prevalence of 34%) could be explained by the inappropriate use of supplements.

### Effectiveness of Professional Fluoride Application

Fluoride products have been applied topically to the teeth of dental patients in the form of solutions, gels, and foams for many years. The fluoride product and protocol with the most data on clinical effectiveness is a 4-minute application of 1.23% sodium fluoride gel applied in a disposable tray that conforms to the dental arch. The effectiveness of this fluoride regimen in the prevention of dental caries in permanent teeth of school-aged children is well established. ^77^ However, adherence to this protocol is very difficult in the treatment of most preschool-aged children because the trays are cumbersome and sometimes uncomfortable for young children, particularly for the required application time, and children can swallow enough of the gel to cause them transient gastric irritation. Because of this latter reason, professional opinion is that gel should not be used in most children under 6 years of age. No clinical trial has tested this standard professional topical fluoride application for caries preventive effectiveness in preschool-aged children.

Fluoride varnish, which was first marketed in the United States in 1994 after the Food and Drug Administration (FDA) approved it as a medical device (as a cavity liner), has overcome these difficulties in the professional application of topical fluorides to the teeth of very young children. Because of the infrequent use of topical fluorides other than fluoride varnish in young children and the absence of clinical trials of the caries preventive effectiveness of other products, the focus of this review is on fluoride varnish alone.

Fluoride varnish was developed in Europe during the 1960s with the aim of prolonging the contact time between fluoride and the tooth surface after professional topical fluoride applications, thereby improving fluoride incorporation into the surface layers of the tooth and prolonging its release into the oral environment. Unlike some other commonly used topical fluoride agents such as gels, varnish can be applied quickly to the teeth without the need of dental devices or equipment. Its use is commonplace in Europe. Four commercial products with 2 fluoride compounds are available—5% sodium fluoride in a natural resin carrier (2.26% F, 22.6 mg/mL F, 22,600 ppm) and 1% difluorsilane in a polyurethane-based resin (0.1% F, 1.0 mg/mL F, 1,000 ppm F).

#### Appropriateness

We identified no study addressing the appropriateness of PCC use of topical fluoride agents. The principal issues related to appropriateness are PCC familiarity with the procedure, patient selection, and adherence to clinical protocol.

Only indirect evidence is available from a single study that partially addresses these issues. ^78^ Of respondents to a national survey of pediatricians, 22% reported that they were familiar with fluoride varnish. Seventy-four percent were willing to consider the use of fluoride varnish once its purpose, clinical procedure, and costs were described briefly, but only 21% agreed that application of fluoride varnish should be part of a well-child care provided by the pediatrician.

#### Parental Agreement

We identified no studies describing PCC effectiveness in obtaining parental agreement for in-office application of topical fluoride. We also were unable to locate any study describing the effectiveness of dentists in obtaining such permission.

Again, only indirect evidence of the effectiveness of providers in gaining patient acceptance is available. ^79^ Twenty-five dental hygienists practicing in Houston, Texas, recruited their patients into a study in which respondents compared fluoride varnish applications in their most recent dental hygiene visit with a previous visit in which fluoride gel was applied. The majority of the 144 patients of unspecified age rated fluoride varnish better than gel on comfort (56.5%) and taste (71.4%). A large percentage of the remaining respondents rated the two items the same. Even though the patients were divided on their assessment of the temporary discoloration resulting from the treatment (51% objecting; 49% not objecting), 64.3% reported that they would choose to have fluoride varnish over gel treatments in subsequent visits. Although this study provides only indirect evidence for effectiveness of PCCs or even dental professionals in obtaining caregivers' agreement for fluoride applications for their children, the results do suggest a higher level of patient acceptance compared to the standard topical fluoride treatment, which should make recommendations for treatment more likely to be followed.

#### Prevention of Dental Caries

Table 8 summarizes 6 clinical trials of the effectiveness of fluoride varnish in preventing dental caries in primary teeth. The table updates a systematic review on the topic completed for the National Institutes of Health (NIH) Caries Consensus Development Conference. ^77^ The original review included 7 papers retrieved from MEDLINE for 1966 through 2000 having primary tooth caries increments in both experimental and control groups. In the updated review, we deleted 2 studies in which treatment began after age 5, and added a 9-month RCT. ^80^ Three of the trials randomized assignment of treatment to groups. The 6 trials tested 2 fluoride products, 2.26% F (Duraphat®) and 0.1% F (Fluor Protector®), compared to negative (untreated) controls.

Table 8A Clinical Studies of Fluoride Varnish Applied to Primary Teeth: Study Design

Study | Country | Design | Fluoride Groups | Application Frequency (times/year) | Other Fluoride Exposures | Number of Examiners | Examiner Reliability | Age at Start of Trial (yrs) | Attrition (%) | Study Length (yrs) | Equality of Groups at Baseline | Blinding | Caries Index^‡^
Holm, 1979 ^96^ | Sweden | RCT, alternate assignment | 2.2% F | 2 | 71% F dentifrice | 1 | NR | 3.0 | 10 | 2 | Yes | Single | defs, x-ray
| | | Duraphat | | 27% F tabs
Grodzka et al, 1982 ^94^ | Poland | Comparison schools, assignment method not specified | 2.2% F | 2 | No other professional topical F | 2 | NR | 3.5 | 20 | 2 | Yes | None | dmfs_1_
| | | Duraphat | | ‘low’ F exposure | | | | | | | | dmfs_2_ partial x-ray
Frostell et al, 1991 ^97^ | Sweden | RCT | 2.2% F | 2 | ‘Most’ use F dentifrice | 2 | NR | 4.0 | NR | 2 | Yes | Examiners | dmfs_2_ interprox x-ray (suicide, invert, neither)
| | | Duraphat with and without invert sugar | | ‘Occasional’ use of F tabs and mouth rinse | | | | | | | | dmfs_1_ (other)
Twetman et al, 1996 ^106^ * | Sweden | Comm. trial: public clinics matched on SES | 0.1% F | 2 | 0.1 ppm F in drinking water | NR | NR | 4.5 | 2 | 2 | Yes | None | dfs excluding maxillary incisors
| | | Fluor Protector | | A ‘few’ given F tablets (0.25 mg F) 95% using F dentifrice.
| | | | | All regular dental visit with counseling
Petersson et al, 1998 ^95^ | Sweden | Comm. trial: public clinics matched on specified criteria | 0.1% F | 2 | 10% with 1.2 ppm F in water. | 24 | NR | 4.5 | 19 | 2 | Yes | None | dfs excluding incisors
| | | Fluor Protector | | >90% using F dentifrice
| | | | | All regular dental visit with counseling
Autio-Gold and Courts, 2001 ^80^ † | United States | RCT | 2.2% F | Baseline and 4 months | 0.8 ppm F in water | 2 | baseline: 79%, k=0.71 | 3–5 | 22 | .75 | Yes | Single | dmfs x-ray
| | | Duraphat | | | | follow-up: 99%, k=0.91 | | | | | | dmfs_2_ x-ray

Note: F, fluoride; comm., community; interprox, interproximal; k, kappa; NR, not reported; ppm, parts per million; RCT, randomized controlled trial; SES, socioeconomic status; defs, decayed, identified for extraction, filled surfaces; dmfs_1_, incipient lesions excluded from count; dmfs_2_, incipient lesions included in count.

* Twetman et al. (1996) also included children from fluoridated community, but their design does not allow determination of fluoride varnish effects.

† Autio-Gold and Courts (2001) is a 9-month study; prevented fraction is adjusted to 12 months.

Table 8B Clinical Studies of Fluoride Varnish Applied to Primary Teeth: Results

Study | Baseline Prevalence | Sample Size | | Caries Increment | | Actual Reduction (per year) | % Reduction | Number Needed to Treat
| | Control Group | Exp Group | Control Group (SD) | Exp Group (SD)
Holm, 1979 ^96^ | 0.71 (C) | 113 | 112 | 3.74 | 2.10 | 0.82 | 43.8 | 1.2
| 1.05 (E) | | | (4.62) | (2.75) | | P<0.01
Grodzka et al, 1982 ^94^ | 9.96 (C) | 100 | 148 | 6.71 | 6.35 | 0.18 | 5.3 | NC
| 9.32 (E) | | | (5.22) | (4.98) | | NS
| 10.35 (C) | 100 | 148 | 6.89 | 6.24 | 0.32 | | NC
| 9.99 (E) | | 6.71 | (5.08) | (4.75)
Frostell et al, 1991 ^97^ | Sucrose | 26 | 37 | 3.27 | 4.27 | +0.50 | +30.5 | NC
| 8.76 (C) | | | | | | NS
| 11.60 (E)
| Invert | 18 | 33 | 1.89 | 3.78 | +0.94 | +50.0 | NC
| 8.83 (C) | | | | | | NS
| 10.18 (E)
| Neither | 113 | 93 | 4.10 | 2.86 | 0.62 | 30.2 | NC
| 8.76 (C) | | | | | | NS
| 11.60 (E)
| 5.14 (C) | 113 | 93 | 3.60 | 2.26 | 0.67 | 37.2 | 1.5
| 4.36 (E) | | | | | | P < 0.01
Twetman et al, 1996 ^106^ * | 1.00 (C) | 374 | 442 | 1.53 | 1.07 | 0.23 | 30.0 | 4.3
| 0.95 (E) | | | (2.55) | (1.96) | | P < 0.05
Petersson et al, 1998 ^95^ | 1.18 (C) | 1916 | 2245 | 1.39 | 1.30 | 0.04 | 6.4 | NC
| 1.13 (E) | | | (2.66) | (2.46) | | NS
Autio-Gold and Courts, 2001 ^80^ | 2.58 (C) | 83 | 59 | 1.47 | 0.54 | 1.24 | 63.2% | 0.8
| 2.51 (E) | | | | | | P < 0.05
| 5.33 (C) | 83 | 59 | 0.38 | -3.59¶ | -4.78 | 67.3% | NC
| 8.22 (E) | | | | | | P < 0.01

Note: C, control group; e, experimental group

§ NS, Not statistically significant.

║ NC, number needed to treat is not calculated for studies with nonsignificant results.

¶ Negative increment in experimental group because of reversal of early caries lesions.

Four trials, including all 3 RCTs, found statistically significant reductions in the number of tooth surfaces with cavitated lesions in the treatment groups. Percentage reductions ranged from 30% to 63.2% in these 4 studies; the actual reduction in affected surfaces ranged from 0.23 to 1.24 per year. Results related to the increments of non-cavitated lesions (incipient lesions) were mixed, with large reductions in one trial, and non-significant increases in two experimental arms of another trial where participants consumed special diets.

#### Risks for Fluorosis

No studies have been published on the risk of enamel fluorosis from the use of fluoride varnish.27 The amount of fluoride in a typical varnish application (0.3 to 0.5 milliliters) varies from 0.3 mg to 11.3 mg.81 Because only a small amount of varnish is applied, the total amount of active agent administered to the patient is markedly reduced compared to other topical fluoride application methods. The plasma fluoride peak after Duraphat® application is only about one-seventh of the peak after application of 1.23% acidulated phosphate fluoride (APF) gel. ^82,^ ^83^ In addition to the small dose, its rapid setting time when it comes in contact with saliva and its dissolution over an extended period of time minimize the risk of acute toxic reactions.

### Effectiveness of Counseling for Caries Prevention

#### Adherence to Recommendations

We found a single study examining PCC effectiveness of early counseling (6 to 12 months) for caries preventive behaviors. ^84^ A quasi-experimental design involved a brief oral health promotional message provided individually by nurses in mother and child health centers compared to negative controls. Pre-post behavioral data were self-report. The intervention was essentially ineffective with respect to bottle use and minimally effective with respect to tooth brushing.

#### Prevention of Dental Caries

We found no study assessing the effectiveness of a PCC-supplied counseling intervention in preventing dental caries.

We examined 4 published systematic reviews of the effectiveness of oral heath promotion and dental health education from the dental literature. One of these reviews included a meta-analysis for an intermediate outcome measure, plaque score. The interventions included in these reviews were conducted by either dental personnel or public health education specialists in institutional settings and mostly for participants older than included in this review. ^85^ – ^88^

Table 9 summarizes the findings of these reviews for knowledge level, oral hygiene behaviors, and caries prevention. Search strategies and inclusion criteria differed across the reviews, but the results were generally similar.

Table 9 Summary of Systematic Reviews of the Effectiveness of Oral Health Promotion and Education

Review | Knowledge Level | Oral Hygiene Behaviors | Caries Prevention
Brown, 1994 ^85^ | Most interventions effective in increasing knowledge in the short-term, little evidence for longer-term effects. | One-on-one instruction, repeated contact, participant involvement lead to short-term improvement, but no longer-term effects. | Reduction in caries if target was use of fluoride-containing product.
OHP and OHE, 57 studies | (3 studies) | (13 studies) | (3 studies)
Kay and Locker, 1996 ^87^ | Knowledge levels consistently raised by interventions; more effective interventions tended to be more expensive. | Plaque removal programs generally effective in short-term, but no long-term benefits. | No evidence that dental health education interventions affect caries levels.
OHE, 37 studies | (14 studies) | (15 studies) | (4 studies)
Sprod,et al., 1996 ^86^ | Knowledge can be easily improved using many approaches, but may fade, may need reinforcement. Has limited effect on behavior change when used alone. | Behavior change effected by active involvement, repetition, continued support. Most effective methods address social, personal environmental, and technical factors. | Very few studies, little evidence of long-term gain.
OHP, 70 studies | (NR) | (NR) | (NR)
Kay and Locker, 1998 ^88^ | Knowledge levels are invariably altered by interventions, but alterations not related to changes in behavior or health. | Simple instruction alters behavior in short-term, reducing plaque levels; no lasting effect. | Meta analysis indicates 1.8 surface reduction associated interventions increasing use of fluorides.
OHP, 164 studies | (NR) | (20 RCTs) | (7 RCTs)

Note: OHP, oral health promotion; OHE, oral health education; NR, number of studies not reported; RCT, randomized controlled trials.

Interventions aimed at increasing knowledge of oral health topics were effective in the short term, but they needed reinforcement over time. However, improvement in knowledge of oral health topics was not related to changes in oral health behavior. Changing oral health behaviors, principally oral hygiene behaviors, could be accomplished by a variety of interventions, but personal one-on-one attention with active involvement was generally the most effective strategy. The effects of interventions designed to alter oral hygiene behaviors are seen only in short-term studies; the effects are lost over periods longer than three to six months without additional intervention. The evidence for effectiveness of oral health education and promotion interventions on dental caries is extremely limited; it is associated almost entirely with adoption of the use of fluoride products. There is no conclusive evidence that interventions designed to improve oral hygiene result in caries reduction.

These reviews examined all available literature concerning oral health education and promotion. Many interventions reviewed were school-based or offered at work. The number of studies identified in the reviews that examined specific effects of dentist or dental hygienist counseling is limited, and the number that focus on dentist or dental hygienist counseling of parents for improving oral hygiene and caries outcomes among preschool children is very small.

Three studies identified by the reviews are relevant. In one, home visits by a dental health educator were more effective in initiation of fluoride supplementation and subsequent reduction of caries than in a no-contact control group and a control group offered fluoride supplementation through visits to the health department. ^89^ However, long-term outcomes were questionable because of 90% attrition. In another study, oral hygiene instructions delivered in mothers' native language at infant ages of 6, 18, and 36 months were not significantly more effective in reducing primary tooth caries than instruction delivered in mothers' adopted language when the mothers were fluent in the adopted language. ^90^ In this study, 3 clinic visits where instructions were reviewed did result in significantly less caries than 2 visits (at 6 and 18 months). The reduction may be attributable to reported adherence with fluoride supplementation as well as more frequent attention to brushing and reduction in soft drinks. In the third study, 3- and 4-year-old children whose parents had received brushing instructions via a home visit from a dental hygienist exhibited plaque index scores comparable to those of children who brushed in small groups under supervision in preschool. Plaque index scores were significantly lower than for a control group with no group brushing or home visits. The combination of home visits and supervised group brushing did not lead to further improvement. ^91^