# Methods

For each of the 5 key questions, we first searched the literature for studies that involved primary care practitioners. Because we anticipated finding only a limited number of studies addressing the performance of PCCs in these essentially dental roles, we also planned from the outset to address Key Questions 3, 4 and 5 using the dental literature. Our approach here was to base the appraisal of the evidence on existing systematic and traditional reviews of the literature whenever possible.

## Studies Involving Primary Care Clinicians

We used separate searches for 3 of the 5 key questions; we combined the 2 fluoride-related questions (Key Questions 3 and 4) into a single search. We searched the English language literature in MEDLINE from 1966 to October 2001. Appendix Tables B3–B6 detail the search terms and numbers of articles produced for each term for each of these searches. We used combinations of (a) terms defining primary care providers or primary care sites and (b) terms defining the dental topics embodied by the individual questions.

Our initial searches included terms capturing a wide range of research designs, from randomized controlled trials (RCTs) through questionnaire surveys. We then added any studies we identified in the Cochrane Controlled Trials Register and those identified through review of the references in papers found by the searches and through personal knowledge.

For each of the resulting 4 sets of papers, 2 reviewers independently reviewed each abstract to identify those studies eligible for full review. Criteria for this level of review were simply that the study addressed the key question, reported original data, and involved primary care practitioners. Papers undergoing full review for inclusion were subjected to the same set of criteria. When we identified studies, we prepared abbreviated evidence tables summarizing their content.

## Studies in the Dental Literature

Because of the small number of studies identified that involved PCCs, we pursued our planned strategy of using a combination of existing reviews and new searches in the dental literature to provide necessarily collateral evidence of effectiveness for 3 questions: supplemental fluoride, applied fluoride, and counseling for caries preventive behaviors. We identified recent systematic reviews that addressed the effectiveness of applied fluoride and counseling.

We could not identify an appropriate review for the effectiveness of prescribed supplemental fluoride for caries reduction in primary teeth, regardless of who made the prescription. Although reviews on the topic were numerous, none included the collection of studies that we thought pertinent to the key question. Therefore, we performed a modified systematic review for this question wherein we identified all possible studies by searching and examining reviews of the topic and then searching forward from the most recent review (Appendix Table B7). We included controlled prospective studies in English in which the intervention began before 5 years of age and investigators assessed outcomes for primary teeth and/or permanent teeth. We accepted the absence of baseline prevalence data when initiation of supplementation occurred before eruption of the primary teeth. The controlled, prospective study criterion excluded more than half of the English language studies traditionally cited in support of the effects of supplementation in primary teeth, which employed retrospective or cross-sectional designs with no assignment or baseline examination (Appendix Table B8). We used a separate recent systematic review of fluorosis associated with the dietary intake of fluorides to assess the harms associated with supplements, as most of the included studies did not address this outcome. ^40^