# Introduction

Issues of oral health in children revolve almost exclusively around dental caries. In the United States, dental caries is the most common chronic childhood disease, ^1^ and its treatment is the most prevalent unmet health need in children. ^2^ A substantial portion of caries lesions can be prevented; indeed, the incidence of this disease has declined among school-age children and adults in the past three decades. However, incidence among preschool children has not declined at a similar rate over this same time period.

## Epidemiology

Dental caries is an infectious disease that can occur when cariogenic bacteria colonize a tooth surface in the presence of dietary carbohydrates, especially refined sugars. The bacteria metabolize the carbohydrates, producing lactic acid, which over time demineralizes the tooth structure. ^3^ The earliest visible manifestation of dental caries is the appearance of a demineralized area on the tooth surface, which presents either as a small white spot on a smooth surface or a pit or fissure. At this stage, a caries lesion is usually reversible. If oral conditions do not change, demineralization will continue with the eventual result that the tooth surface loses its natural contour and a “cavity” develops. At this stage, restorative treatment is necessary to prevent the continuation of the caries process, which if left untreated will eventually result in pulpitis and ultimately tooth loss.

Progression of individual caries lesions is typically slow, but it can be extremely rapid in a small proportion of individuals and especially in primary teeth, which have thinner enamel. Because dental caries is a chronic disease of microbial origin, modified by diet, the elimination of active caries lesions through treatment does not necessarily mean that the disease has been eradicated. An individual's risk for dental caries can change with time as etiologic factors change, leading to new caries events around already treated lesions or on previously unaffected tooth surfaces.

Dental caries can occur soon after eruption of the primary teeth, starting at 6 months of age. The most recent national survey (1988-1994) indicated that 52% of children 5 to 9 years of age have experienced dental caries; ^4^ of children 2 to 5 years of age, 18.7% have at least 1 primary tooth with untreated decay. ^5^ Referred to as early childhood caries (ECC), dental caries in preschool children can take several forms. The most severe form has a pattern of early initial attack on the maxillary incisors with the attack continuing on other teeth as they erupt. ^6^

Dental caries incidence begins in the permanent teeth at about 6 years with the eruption of central incisors and first molars. Among children 5 to 11 years of age, 26% have experienced one or more lesions in permanent teeth; this proportion increases to 67% among adolescents 12 to 17 years of age. ^7^

Dental caries is unequally distributed among the population. Caries incidence, prevalence, and severity is greater in minority and economically disadvantaged children. ^2,^ ^4,^ ^5,^ ^8^ Among children 1 to 2 years of age examined in the most recent national survey, all who had obvious dental caries in the maxillary incisors were in the group with incomes at or below 200% of the federal poverty line. ^9^ Among children 2 to 5 years of age, those in families at or below the poverty level are 106% more likely to have experienced dental caries than children in families with incomes above the poverty level. ^5^ At this same age, black children have 43% more untreated carious primary teeth than white children, and children at or below the federal poverty line have 138% more than children above the poverty line. ^10^

Dental caries in primary teeth can has both short- and longer-term negative consequences. Caries lesions often cause pain because they can progress rapidly in primary teeth and involve the pulp before they are either detected or treated. About 1 in 10 children 2 to 17 years of age and 1 in 5 children from low-income families made dental visits because they were in pain or something was bothering them. ^11^ Regardless of their degree of progression, lesions cavitated into dentin require reparative treatment or tooth extraction; both are frequently traumatic experiences for young children. Young children with untreated, symptomatic carious teeth often present to emergency departments of hospitals for their first dental visit. ^12^ Also, untreated caries lesions in young children may be associated with failure to thrive, ^13^ although evidence is conflicting regarding this association. ^14^ Social outcomes of dental caries in young children are poorly documented, but children 5 to 7 years of age in the United States have been estimated to lose more than 7 million school hours annually because of dental problems and/or visits. ^15^ Untreated caries typically is cited as leading to increased infections, dysfunction, poor appearance, and low self-esteem, ^16^ but most of these associations stem from conventional wisdom rather than observational studies.

Longer-term consequences of dental caries in primary teeth include an increased probability of caries in the permanent dentition ^17,^ ^18^ and possible loss of arch space. Lack of treatment for caries in primary teeth will often result in the premature loss of the primary teeth, especially molars, which are at risk for the longest period. Premature loss of primary molars can lead to loss of arch space as the first permanent molars drift into the missing tooth spaces. ^19^ The result can be crowding of the permanent teeth, the severity of which depends on the amount of lost space. Anterior tooth crowding affects aesthetics and may necessitate orthodontic treatment for correction.

Some dentists believe that crowding increases the risk of both caries and periodontal disease in the permanent dentition because of the disruption of normal tooth-to-tooth relations that promote self-cleaning. This widely held belief is not well supported by observational studies, however.

## Prevention

Approaches to the prevention of dental caries involve attempts to reduce the microbiological burden, reduce the availability of refined sugars, increase the resistance of teeth, or some combination of these approaches. Reducing the microbiological burden is the focus of interventions using antimicrobial rinses and dentifrices and behavioral interventions to improve oral hygiene and thus remove the bacterial plaque coating tooth surfaces. Behavioral interventions are also used to reduce the availability of fermentable carbohydrates through changes in the composition of the diet and frequency of ingestion of refined sugar. Increasing the resistance of teeth is typically achieved through the use of sealants and fluorides. Sealants are applied to the occlusal surfaces of molars and premolars, denying bacteria access to these often hard-to-clean areas. Fluorides are used both topically (fluoride dentifrices, rinses, gels, foams, and varnishes) and systemically (fluoridated water, dietary fluoride supplements) for both prevention and management (i.e., remineralization) of dental caries. After exposure, fluoride becomes available in plaque, saliva, and the tooth's outer layer, where it increases resistance to acid dissolution, serves as a reservoir for remineralization of the initial caries lesions, or acts as a bacterial inhibitor when released through acid dissolution. ^3,^ ^20^ Another approach currently receiving attention but not yet widely endorsed attempts to eliminate transmission of cariogenic bacteria from caregiver to child through the use of antimicrobial and behavioral interventions to reduce the reservoir of bacteria in the caregiver. ^21,^ ^22^

## Guidelines for Prevention of Dental Caries

A growing number of guidelines provide recommendations on individual, professional, and community interventions to prevent and control dental caries. ^4,^ ^23^ – ^30^ Most recently, the Task Force on Community Preventive Services has supported the effectiveness and safety of community water fluoridation; like several of the more recent guidelines, this statement is based on systematic reviews of the evidence of effectiveness and safety. ^31^

In 1996, the U.S. Preventive Services Task Force (USPSTF) recommended (in Chapter 61 of the Guide to Clinical Preventive Services) counseling patients to visit a dental care provider on a regular basis, floss daily, and brush their teeth daily with fluoride-containing toothpaste based on evidence of risk reduction from these interventions. ^32^ The USPSTF also recommended counseling caregivers to avoid putting infants and children to bed with a bottle. Dietary fluoride supplementation (hereafter referred to as fluoride supplementation) of persons 6 months to 16 years of age who drink water with inadequate fluoride was recommended based on well-designed controlled trials.

The 1995 Canadian Task Force on Preventive Health Care (CTFPHC) focused on dental interventions per se; they recommended water fluoridation, fluoride supplementation in low-fluoride areas, professional topical fluoride, and self-administered fluoride mouth rinses for persons with active decay or specific risk factors, and use of fluoride dentifrice. ^24^

An expert panel convened by the Centers for Disease Control and Prevention (CDC) recently conducted a critical analysis of scientific evidence regarding the efficacy and effectiveness of fluoride modalities in the prevention and control of dental caries. ^27^ Fluoride toothpaste, mouth-rinse, gel, and varnish were recommended based on the quality of the evidence of effectiveness. For the first time, the evidence of effectiveness for fluoride supplements was graded according to age. Prenatal supplements were not recommended based on the results of a single randomized controlled trial. Supplements were recommended for children and adults, but only for those at high risk for dental caries. The evidence for caries prevention was judged to be good for school-aged children and poor for preschool-aged children and adults; but targeting high-risk patients was based on expert opinion alone.

The American Academy of Pediatrics (AAP) has endorsed the CDC fluoride guidelines, thus supporting (a) community water fluoridation and fluoride toothpaste for use by the general population and (b) targeted use of professional fluoride products, including prescription of dietary fluoride supplements. ^30^ The American Dental Association (ADA) in one of its widely distributed publications also recommended limiting the use of dietary fluoride supplements and other professional fluoride products to patients with moderate to high caries risk (i.e., having 1 or more risk indicators for dental caries). ^23^ Guidelines on fluoride therapy published by the American Academy of Pediatric Dentistry (AAPD) are not specific on use of fluoride according to caries risk. ^25^ Other than the CDC fluoride guidelines for dietary fluoride supplements and fluoridated toothpaste, none of these guides is specific to young children. Appendix B provides a comparison of guidelines for supplements (Appendix Table B1) and professional application of fluorides (Appendix Table B2).

## Access

Several dental organizations, including the AAPD and the ADA, recommend a first dental visit when a child is about 1 year of age. ^33^ Bright Futures recommends a dental appointment beginning at 12 months of age also, a stance that is endorsed by more than two dozen health organizations. ^34^ Available information suggests that the majority of children see a dentist for the first time rather later in life, but national data on age at first dental visit are not available. Data from the Medical Expenditures Panel Survey and the National Health and Nutrition Examination Survey describe proportions of the child population 2 to 5 years of age who had a visit in the past year; estimates vary from 20% ^35^ to 30%, ^36,^ ^37^ suggesting that the mean age at first visit is more likely between 3 and 5 years. More recent data will be necessary to determine if the public and dental professions are following the newer guidelines on age at first dental visit.

Access to dental care for young children enrolled in Medicaid is a particularly severe problem. Of children 1 to 5 years of age enrolled in the Early and Periodic Screening, Diagnostic and Treatment (EPSDT) Program, 16% receive any preventive dental care even though all are eligible for these benefits. ^4^ A large percentage of young children with early childhood caries are able to get only emergency dental services, at best. A study of North Carolina's Medicaid population found that as few as 2% of 3-year-old enrolled children received comprehensive care in a 12-month period. ^38^

Reasons for the poor access that young children have to dental services are numerous and complex. Two situations in particular contribute to the access problem. First, general dentists are reluctant to treat young children; only a limited number of dentists have specialty training in their care. About 3,600 pediatric dentists nationwide supply 1 pediatric dentist for every 6,000 children younger than 6 years of age. ^11^ Second, in most states, Medicaid reimburses dentists only a fraction of their usual, reasonable, and customary charges, making the treatment of any Medicaid patients financially unattractive.

Compounding the problems of access to care for Medicaid and uninsured children is that the dental safety net does not function well in most areas of the country. Local, state, and federal dental programs have limited resources to meet the dental needs of those populations with limited access to private dental care. ^4^ For example, 4 major federal programs target underserved populations: the Health Center program that funds community and migrant health centers, the Indian Health Service dental program, and the National Health Service Corps and Indian Health Service loan repayment programs, both of which provide incentives for dental providers to practice in medically underserved areas. The General Accounting Office assessed all of these programs as having only a limited effect on improving access to dental services for their targeted populations. ^36^

Use of ambulatory health care in the medical office setting during the first year of life and from 1 to 4 years is 78% and 84.1%, respectively. ^39^ Use of dental care is 0% and 19.2%, respectively, for these same 2 age groups, demonstrating the large difference in utilization of medical care and dental care by young children. Problems with access to dental care underscore the role that primary care physicians and other child health care providers can play in providing access to preventive dental services, particularly for very young children and those who do not have access to dental care. Among young children who have experienced dental caries, a professional preventive intervention for dental caries presumably would have reduced or eliminated the incidence of disease. Yet, many children do not make a dental visit until well after the disease has progressed beyond the reversible stage. Also, those least likely to make an early dental visit are those most likely to have dental caries.

Physicians and other primary care clinicians (PCCs) see child patients during this at-risk age before the first dental visit, providing an opportunity for them to take preventive action. Recommendations for physician interventions addressing dental caries include oral health screening and referral when indicated, provision of oral hygiene, dietary information, and anticipatory guidance to parents, and prescription of fluoride supplements. ^30,^ ^34^ PCCs also now apply fluoride varnish.

The USPSTF has limited its consideration of dental health to issues associated with prevention of dental caries in preschool children. Although the complete scope of prevention of dental diseases is much wider, the rationale for focusing on preschool children and dental caries is compelling. As noted, physicians have a role in providing dental preventive services to young children. Physicians are much more likely to see preschool children than are dentists, a situation that does not reoccur until late in life. The caries process can start at an age when most children have not visited a dentist, reducing the potential for preventive interventions by dentists and permitting extensive destruction before dental intervention. Well-defined preventive procedures within the scope of medical practice are available for physicians to utilize in this preschool population.

Thus, a sound theoretical basis exists for a focus on the role of physicians in the prevention of dental caries in preschool children. This review is not intended to suggest that the role of the physician should supplant the role of the dentist in maintaining the oral health of preschool children. Rather, the fundamental assumption of the review is that the responsibility for management of a child's oral health is shared among PCCs and dentists, and major responsibility is transferred from a PCC to a dentist at a point in time arranged jointly by the PCC, parents, and dentist.

This report represents a departure from the chapter on Oral Health that appeared in the 1996 edition of the Guide to Clinical and Preventive Services. That chapter focused on counseling for the prevention of dental diseases in all ages. This summary of evidence focuses exclusively on the evidence of effectiveness for procedures applied by physicians and other primary care clinicians to prevent carious lesions in young children.

Because of these different emphases, many of the recommendations from the 1996 Guide to Clinical and Preventive Services are not reexamined in this report.

## Analytic Framework and Key Questions

The analytic framework for this review (Figure 1) represents a risk-based approach to the prevention and management of dental caries. It begins with a child's visit to a PCC, presumably a well-child visit. The PCC screens the child for both the presence of dental caries and risk indicators for dental caries. Depending on the results of the screening (either identification of suspected caries lesions or recognition of elevated risk for dental caries), the physician either refers the child to a dentist or initiates one or more preventive interventions (prescription of supplemental fluorides, application of fluoride varnish in the office, counseling the parents concerning caries preventive behaviors). The counseling intervention may include referral as well. If no disease or risk factors are identified, the PCC may also undertake counseling. This arm as well as the outcomes of treatment by dental professionals, are shown by dotted lines, indicating that we did not evaluate them in this review.

Figure 1. Dental Care for Young Children from Primary Care Physicians: Analytic Framework

^a^ Suspected disease:The PCC either visually identifies one or more cavitated lesions, or suspects that such a condition is present.

^b^ Elevated risk: The PCC identifies one or more risk indicators such as:

- inadequate fluoride exposure
- caries in siblings or parents
- irregular brushing/plaque retention
- white spots on smooth tooth surfaces
- frequent/prolonged carbohydrate exposure
- special needs/medical conditions that increase risk
- lower socioeconomic status

The framework is intended to outline general types of interventions that PCCs provide and that are appropriate to children between birth and 5 years of age. Although prenatal counseling is recommended by some professional health care organizations and may be appropriate, it is not a focus of this review. Similarly, application of dental sealants, another effective dental care preventive service, is outside the scope of the review because it is unlikely to be feasible for PCCs to provide this service.

We developed 5 key questions to direct the review.

1 How accurate is PCC screening in identifying children ages 0 to 5 years who:
  (a) have dental caries requiring referral to a dentist?
  (b) are at elevated risk of future dental caries?

2 How effective is PCC referral of children ages 0 to 5 years to dentists in terms of the proportion of referred children making a dental visit?
3 How effective is PCC prescription of supplemental fluoride in terms of:
  (a) appropriateness of supplementation decision?
  (b) parental adherence to the dosage regimen?
  (c) prevention of dental caries?

4 How effective is PCC application of fluoride in terms of:
  (a) appropriateness of application decision?
  (b) achieving parental agreement for the application?
  (c) prevention of dental caries?

5 How effective is PCC counseling for caries-preventive behaviors as measured by:
  (a) adherence to the desired behavior?
  (b) prevention of dental caries?

For Key Question No. 5, the caries-preventive behaviors of interest relate to diet (reduction in frequency and amount of sucrose, appropriate use of the bottle), oral hygiene (brushing frequency and efficacy), dental attendance (regular dental examinations and first visits for assessment of risk of disease), appropriate use of fluoride (accepting professional recommendations, use of fluoride dentifrice at home), and implications of caregiver oral health (possible transmission of cariogenic bacteria).