# Appendix B

Appendix Table B1. Recommendations on Use of Daily Dietary Fluoride Supplementation

Organization | Dosage Schedule | Risks | Level of Evidence | Recommendation
USPSTF, 1996 ^32^ | ADA and AAP 1995 guidelines. | Increase in the prevalence of dental fluorosis has been attributed to inappropriate use of fluoride supplements by health professionals and parents, which is particularly common among infants. | Nonrandomized controlled trials (II-1). | For children <16 years living in an area with inadequate water fluoridation (<0.6 ppm), the prescription of daily fluoride drops or tablets is recommended (A).
CTFPHC, 1995 ^24^ | CDA guidelines. | Inappropriate prescribing of excess fluoride supplements is the main factor in recent increases in the incidence of fluorosis. | Nonrandomized controlled trials (II-1). The new lower dosage schedule approved by the Canadian Dental Association has not been subjected to clinical trials. | Good evidence of reductions in the incidence of decay if the proper dosage schedule is carefully followed (A).
CDC, 2001 ^27^ | ADA, AAPD, and AAP 1995 guidelines. | For children aged <6 years, the dentist, physician, or other health-care provider should weigh the risk for caries without fluoride supplements, the caries prevention offered by supplements, and the potential for enamel fluorosis. | The evidence for using fluoride supplements to mitigate dental caries is mixed. Use of fluoride supplements by pregnant women does not benefit their offspring (I). | Fluoride supplements can be prescribed for children at high risk for dental caries and whose primary drinking water has a low fluoride concentration
| | | Many studies of the effectiveness of fluoride supplements in preventing dental caries among children aged <6 years have been flawed in design and conduct. Because of these flaws, the quality of evidence to support use of fluoride supplements by children aged <6 years is Grade II-3. | (C high-risk children <6 yrs; A high risk children 6–16 yrs; C high risk >16 yrs; E pregnant women).
| | | Among children aged 6–16 years, fluoride supplements taken after teeth erupt reduce caries experience (I).
| | | Fluoride supplements might be beneficial among adults who have limitations with toothbrushing, but this use requires further study.
AAP, 2001 ^30^ | Endorses CDC fluoride recommendations
AAPD, 2000 ^25^ | ADA, AAPD, and AAP 1995 guidelines. | | | Should be considered for all children drinking fluoride deficient water.

Note: USPSTF, U.S. Preventive Services Task Force; CTFPHC, Canadian Task Force on the Preventive Health Care; CDC, Centers for Disease Control and Prevention; AAP, American Academy of Pediatrics; AAPD, American Academy of Pediatric Dentistry; ADA, American Dental Association

Appendix Table B2. Recommendations on the Use of Professional Topical Fluoride Applications

Organization | Agent | Risks | Evidence | Recommendation
USPSTF. 1996 ^32^ | Topical fluorides | Not evaluated
CTFPHC, 1995 ^24^ | Topical fluorides, e.g., APF gel | | RCTs (I) involving mainly children & adolescents conducted before incidence of caries declined. | For use in those with very active decay or a high risk of caries, since their ds. mimics that in general population before decline.
| 1–2 time per yr
NIH Consensus Statement, 2001 ^104^ | APF gel | | Consistently positive.
| 1–2 times per yr
| Fluoride varnish | | Permanent teeth—generally positive
| | | Primary teeth—Incomplete and inconsistent
CDC Fluoride Recommendations, 2001 ^27^ | Fluoride gel | Because application is infrequent, poses little risk for fluorosis. | RCTs (Grade I) | Important in the prevention and control of caries in high-risk persons. Likely to have little benefit in person not at high risk (A).
| Fluoride varnish | No evidence that it is a risk factor for fluorosis. | RCTs (Grade I) | If approved by the FDA for prevention of caries, indications for use will be similar to gel (i.e., high risk). Has practical advantages for <6.
Scottish Intercollegiate Guidelines Network, 2000* ^26^ | Fluoride varnish | | At least one RCT (Level Ib) | May be applied every 4–6 mo to teeth of high-caries-risk children (B)

Note: USPSTF, U.S. Preventive Services Task Force; CTFPHC, Canadian Task Force on the Preventive Health Care, National Institutes of Health; CDC, Centers for Disease Control and Prevention; FDA, Food and Drug Administration; RCT, randomized controlled trials

* Review limited to permanent teeth of children 6 to 16 years of age. Topical fluorides other than varnish were not addressed.

Appendix Table B3. Search Strategy: Screening for Dental Caries (Key Question No. 1)

Step | Search History | Number of Articles
1 | Explode physicians | 42,299
2 | Explode pediatrics/ or pediatrician$.mp | 20,495
3 | Explode nurse practitioners | 8,419
4 | Explode nurse's aides | 2,512
5 | Explode physician assistants | 3,087
6 | Explode nurse clinicians | 3,874
7 | Nurses | 17,410
8 | Primary care physician$.mp. | 5,771
9 | General practitioner$.mp. | 15,510
10 | Primary care clinician$.mp. | 215
11 | Explode ambulatory care facilities | 26,003
12 | Explode primary health care | 30,950
13 | Explode physician's role | 14,507
14 | Explode physician's practice patterns | 11,285
15 | Explode mass screening | 51,371
16 | Explode health behavior | 32,461
17 | Explode health promotion | 19,365
18 | Explode infant welfare | 424
19 | Explode health services accessibility | 40,624
20 | Explode child health services | 11,926
21 | Explode child health services | 11,926
22 | Explode “referral and consultation” | 31,229
23 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 | 334,557
24 | Limit 23 to (human and english language) | 227,440
25 | Limit 24 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or evaluation studies or meta analysis or multicenter study or randomized controlled trial or technical report or validation studies) | 10,765
26 | Explode epidemiologic study characteristics | 770,784
27 | Explode epidemiologic research design | 277,013
28 | Explode questionnaires | 86,495
29 | (26 or 27 or 28) and 24 | 47,943
30 | 25 or 29 | 51,804
31 | Explode dental caries | 23,407
32 | Dental screening.mp. Or explode dental care for children | 842
33 | Explode dental care/ or dental examination.mp. Or explode diagnosis, oral | 27,796
34 | 31 or 32 or 33 | 48,933
35 | 34 and 30 | 497
36 | Limit 35 to (infant <1 to 23 months> or preschool child <2 to 5 years>) | 117
37 | From 36 keep 1–117 | 117

Appendix Table B4. Search Strategy: Referral for Dental Care (Key Question No. 2)

Step | Search History | Number of Articles
1 | Explode physicians | 42,299
2 | Explode pediatrics/ or pediatrician$.mp. | 20,495
3 | Explode nurse practitioners | 8,419
4 | Explode nurse's aides | 2,512
5 | Explode physician assistants | 3,087
6 | Explode nurse clinicians | 3,874
7 | Nurses | 17,410
8 | Primary care physician$.mp. | 5,771
9 | General practitioner$.mp. | 15,510
10 | Primary care clinician$.mp. | 215
11 | Explode ambulatory care facilities | 26,003
12 | Explode primary health care | 30,950
13 | Explode physician's role | 14,507
14 | Explode physician's practice patterns | 11,285
15 | Explode mass screening | 51,371
16 | Explode health behavior | 32,461
17 | Explode health promotion | 19,365
18 | Explode infant welfare | 424
19 | Explode health services accessibility | 40,624
20 | Explode child health services | 11,926
21 | Explode child health services | 11,926
22 | Explode "referral and consultation" | 31,229
23 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 24 limit 23 to (human and english language) | 227,440
25 | Limit 24 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or evaluation studies or meta analysis or multicenter study or randomized controlled trial or technical report or validation studies) | 10,765
26 | Explode epidemiologic study characteristics | 770,784
27 | Explode epidemiologic research design | 277,013
28 | Explode questionnaires | 86,495
29 | (26 or 27 or 28) and 24 | 47,943
30 | 25 or 29 | 51,804
31 | Explode MOTHERS | 8,839
32 | Explode PARENTS | 27,870
33 | 31 or 32 | 27,870
34 | Explode dental health services/ or dental utilization.mp. Or explode dental care | 19,128
35 | 30 and 34 | 438
36 | Limit 35 to (infant <1 to 23 months> or preschool child <2 to 5 years>) | 92
37 | 33 and 35 | 22
38 | 36 or 37 | 102

Appendix Table B5. Search Strategy: Fluoride Prescription and Application (Key Question Nos. 3 and 4)

Step | Search History | Number of Articles
1 | Explode physicians | 48,669
2 | Explode pediatrics/ or pediatrician$.mp. | 24,373
3 | Explode nurse practitioners | 8,436
4 | Explode nurse's aides | 2,521
5 | Explode physician assistants | 3,113
6 | Explode nurse clinicians | 3,891
7 | Nurses | 17,980
8 | Primary care physician$.mp. | 5,864
9 | General practitioner$.mp. | 15,688
10 | Explode physicians, family | 8,489
11 | Primary care clinician$.mp. | 217
12 | Explode ambulatory care facilities | 26,115
13 | Explode primary health care | 31,703
14 | Explode physician's role | 16,055
15 | Explode physician's practice patterns | 11,495
16 | Explode mass screening | 53,682
17 | Explode health behavior | 35,622
18 | Explode health promotion | 19,558
19 | Explode infant welfare | 444
20 | Explode health services accessibility | 43,806
21 | Explode child health services | 11,981
22 | Explode "referral and consultation" | 32,015
23 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 | 353,428
24 | Limit 23 to (human and english language) | 234,983
25 | Limit 24 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or evaluation studies or meta analysis or multicenter study or randomized controlled trial or technical report or validation studies) | 10,995
26 | Explode epidemiologic study characteristics | 775,270
27 | Explode epidemiologic research design | 279,029
28 | Explode questionnaires | 87,784
29 | (26 or 27 or 28) and 24 | 49,240
30 | 25 or 29 | 53,190
31 | Explode mothers | 9,310
32 | Explode parents | 30,640
33 | 31 or 32 | 30,640
34 | Explode fluorides, topical | 3,044
35 | Explode fluorides | 18,617
36 | Explode cariostatic agents | 20,675
37 | Supplemental fluoride$.mp. | 25
38 | Fluoride tab$.mp. | 263
39 | Fluoride drop$.mp. | 10
40 | Fluoride varnish$.mp. | 197
41 | 34 or 35 or 36 or 37 or 38 or 39 or 40 | 21,167
42 | 30 and 41 | 71
43 | Limit 42 to (newborn infant <birth to 1 month> or infant <1 to 23 months> or preschool child <2 to 5 years>) | 31
44 | 42 and 33 | 5
45 | 43 or 44 | 31

Appendix Table B6. Search Strategy: Conseling for Caries Preventive Procedures (Key Question No. 5)

Step | Search History | Number of Articles
1 | Explode physicians | 48,669
2 | Explode pediatrics/ or pediatrician$.mp. [mp=title, abstract, registry number word, mesh subject heading] | 24,373
3 | Explode nurse practitioners | 8,436
4 | Explode nurse's aides | 2,521
5 | Explode physician assistants | 3,113
6 | Explode nurse clinicians | 3,891
7 | Explode nurses | 42,028
8 | Primary care physician$.mp. | 5,864
9 | General practitioner$.mp. | 15,688
10 | Primary care clinician$.mp. | 217
11 | Explode ambulatory care facilities | 26,115
12 | Explode primary health care | 31,703
13 | Explode physician's role | 16,055
14 | Explode physician's practice patterns | 11,495
15 | Explode mass screening | 53,682
16 | Explode health behavior | 35,622
17 | Explode health promotion | 19,558
18 | Explode infant welfare | 444
19 | Explode health services accessibility | 43,806
20 | Explode child health services | 11,981
21 | Explode "referral and consultation" | 32,015
22 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 | 364,755
23 | 22 | 364,755
24 | Limit 23 to (human and english language) | 243,800
25 | Limit 24 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or evaluation studies or meta analysis or multicenter study or randomized controlled trial or technical report or validation studies) | 11,058
26 | Explode epidemiologic study characteristics | 775,270
27 | Explode epidemiologic research design | 279,029
28 | Explode questionnaires | 87,784
29 | (26 or 27 or 28) and 24 | 50,034
30 | 25 or 29 | 54,008
31 | Explode mothers | 9,310
32 | Explode parents | 30,640
33 | 31 or 32 | 30,640
34 | Explode dental care for children | 805
35 | Explode dental caries | 23,439
36 | Explode oral hygiene | 9,346
37 | Explode oral health | 4,812
38 | Explode health education, dental | 4,518
39 | Explode diet, cariogenic/ | 973
40 | Explode dental care | 15,676
41 | 34 or 35 or 36 or 37 or 38 or 39 or 40 | 49,286
42 | 30 and 41 | 630
43 | Limit 42 to (infant <1 to 23 months> or preschool child <2 to 5 years>) | 121
44 | 33 and 42 | 41
45 | 43 or 44 | 137

Appendix Table B7. Reviews of Fluoride Supplements for Caries Reduction*

Step | Search History | Number of Articles
1 | Fluoride supplementation.mp | 147
2 | Fluoride supplement$.mp | 402
3 | Fluoride tab$.mp | 263
4 | Explode Fluorides/ and Explode Dietary Supplements | 649
5 | 1 or 2 or 3 | 56
6 | 4 or 5 | 670
7 | Limit 6 to (human and English language and review articles)
8 | Limit 6 to rvidence-based medicine reviews or all embr articles reviews or topic reviews <cochrane> or article reviews <acp journal club> or article reviews <dare> | 1
9 | 7 or 8 | 64

* The search was repeated from 1995 to January 2002 seeking all publication types limited to human and English language.

Appendix Table B8. Fluoride Supplement Review, Excluded English Language Studies*

Study | Reason
Awad et al., 1994 ^107^ | No negative control
Kalsbeek H et al., 1992 ^108^ | Cross-sectional, poor exposure history
Widenheim & Birkhed 1991 ^109^ | Cross-sectional data
D'Hoore & Van Nieuwenhuysen 1992 ^110^ | Cross-sectional, no primary teeth data, mixed exposure analysis
Mann et al., 1989 ^111^ | Subjects <5 and >5 at baseline combined
de Liefde & Herbison 1989 ^112^ | Cross-sectional, no primary tooth data, poor exposure data
Bagramian et al., 1989 ^113^ | Cross-sectional, no primary tooth data, initiation age not specified
O'Rourke et al, 1988 ^114^ | Mean child age >5 years at baseline
Widenheim et al., 1986 ^115^ | Cross-sectional, no primary tooth data
Petersson et al., 1985 ^116^ | No negative control
Friis-Hasché et al., 1984 ^117^ | Cross-sectional, poor exposure data, inadequate exposure
Holm & Andersson, 1982 ^118^ | Cross-sectional, no primary tooth data
Fanning et al., 1980 ^119^ | Cross-sectional
Thylstrup et al., 1979 ^120^ | Cross-sectional, poor exposure data
Granath et al., 1978 ^121^ | Cross-sectional
Andsenden & Grahne, 1976 ^122^ | Cross-sectional
Fanning et al., 1975 ^61^ | Cross-sectional
Aasenden & Peebles, 1974 ^123^ | Cross-sectional
Pritchard, 1969 ^124^ | Cross-sectional, exposure determination method not described
Kailis et al., 1968 ^125^ | Cross-sectional, fluoride exposure data inadequate
Hennon et al., 1967 ^126^ | Cross-sectional
Minoguchi et al., 1963 ^127^ | Cross-sectional, no primary tooth data, initiation age not specified
Arnold et al., 1960 ^128^ | No concurrent control

* From those included in previous reviews and those identified post 1985.