# Appendix A: Acknowledgments

This study was supported by Contract 290-97-0011 from the Agency for Healthcare Research and Quality (Task No. 3). We acknowledge at AHRQ the continuing support of Jacqueline Besteman, JD, MA, Program Officer for the Evidence-based Practice Center program; David Atkins, MD, MPH, Chief Medical Officer of the AHRQ Center for Practice and Technology Assessment; and Jean Slutsky, PA, MSPH, Task Order Officer for the USPSTF project. In addition, we would like to thank our USPSTF Liaisons, Paul Frame, MD, Charlie Homer, MD, MPH, and Tracy Orleans, PhD, for their guidance during the research process. The investigators deeply appreciate the considerable support and contributions of members of the Research Triangle Institute staff: Linda Lux, MPA, and Sonya Sutton, BSPH, for substantive and editorial work, and Loraine Monroe, for superior secretarial assistance. In addition, we are indebted to staff from the University of North Carolina at Chapel Hill and the Cecil G. Sheps Center for Health Services Research: Audrina Bunton for administrative assistance and coordination, and Timothy S. Carey, MD, MPH, Director of the Sheps Center and Co-Director of the RTI-UNC Evidence-based Practice Center.

We also owe our thanks to the following external peer reviewers, who provided constructive feedback and insightful suggestions for improvement of this systematic evidence review: Doug Campos-Outcalt, MD, Amerian Academy of Family Physicians, Chevy Chase, MD; Patricia Evans, MD, MPH, San Francisco Department of Public Health, San Francisco, CA; James Leake, DDS, MSc, The University of Toronto, Toronto, ON, Canada; Burton Edelstein, DDS, MPH, Director, Division of Community Health, New York, NY; Jane Weintraub, DDS, MPH, University of California at San Francisco, San Francisco, CA; Eugenio Beltran, DDS, DrPH, Atlanta, GA; Mark E. Mallatt, DDS, MSD, State Oral Health Director, Indianapolis, IN; and Steven Adair, DDS, MS, Medical College of Georgia, Augusta, GA.