# References

1 Sedlak AJ, Broadhurst DD. Third National Incidence Study of Child Abuse and Neglect: Final Report. Washington, DC: U.S. Dept of Health and Human Services, National Center on Child Abuse and Neglect; 1996.
2 Child Maltreatment 1999: Reports from the States to the National Child Abuse and Neglect Data System. Washington, DC: U.S. Department of Health and Human Services; 2001.
3 Fergusson DM, Horwood LJ, Woodward LJ. The stability of child abuse reports: a longitudinal study of the reporting behaviour of young adults. Psychol Med. 2000;30(3):529-544. [pmid: 10883709].
4 Felitti VJ, Anda RF, Nordenberg D, et al. Relationship of childhood abuse and household dysfunction to many of the leading causes of death in adults. The Adverse Childhood Experiences (ACE) Study. Am J Prev Med. 1998;14(4):245-258. [pmid: 9635069].
5 The 1996 Federal Child Abuse Prevention and Treatment Act (CAPTA). 1996.
6 McGuigan WM, Pratt CC. The predictive impact of domestic violence on three types of child maltreatment. Child Abuse Negl. 2001;25(7):869-883. [pmid: 11523866].
7 Brown J, Cohen P, Johnson J. A longitudinal analysis of risk factors of child maltreatment: findings of a 17-year prospective study of officially recorded and self-reported child abuse and neglect. Child Abuse Negl. 1998;22:1065-1078. [pmid: 9827312].
8 Kotch JB, Browne DC, Ringwalt CL, et al. Risk of child abuse or neglect in a cohort of low-income children. Child Abuse Negl. 1995;19(9):1115-1130. [pmid: 8528817].
9 Cadzow SP, Armstrong KL, Fraser JA. Stressed parents with infants: reassessing physical abuse risk factors. Child Abuse Negl. 1999;23(9):845-853. [pmid: 10505899].
10 Mammen OK, Kolko DJ, Pilkonis PA. Negative affect and parental aggression in child physical abuse. Child Abuse Negl. 2002;26(4):407-424. [pmid: 12092806].
11 Dubowitz H. Preventing child neglect and physical abuse: a role for pediatricians. Pediatr Rev. 2002;23(6):191-196. [pmid: 12042593].
12 Violence by Intimates: Analysis of Data on Crimes by Current or Former Spouses, Boyfriends, and Girlfriends: U.S. Department of Justice; 1998.
13 The Commonwealth Fund. First Comprehensive National Health Survey of American Wome; 1993.
14 The Commonwealth Fund. Health Concerns Across A Woman's Lifespan: The Commonwealth Fund 1998 Survey of Women's Health; 1999.
15 Gin NE, Rucker L, Frayne S, Cygan R, Hubbell FA. Prevalence of domestic violence among patients in three ambulatory care internal medicine clinics. J Gen Intern Med. 1991;6(4):317-322. [pmid: 1890502].
16 Rath GD, Jarratt LG, Leonardson G. Rates of domestic violence against adult women by men partners. J Am Board Fam Pract. 1989;2(4):227-233. [pmid: 2801190].
17 Martins R, Holzapfel S, Baker P. Wife abuse: Are we detecting it?. J Womens Health. 1992;1(1):77-80.
18 Hamberger LK, Saunders DG, Hovey M. Prevalence of domestic violence in community practice and rate of physician inquiry. Fam Med. 1992;24(4):283-287. [pmid: 1601239].
19 Abbott J, Johnson R, Koziol-McLain J, Lowenstein SR. Domestic violence against women. Incidence and prevalence in an emergency department population. JAMA. 1995;273(22):1763-1767. [pmid: 7769770].
20 McCauley J, Kern DE, Kolodner K, et al. The “battering syndrome”: prevalence and clinical characteristics of domestic violence in primary care internal medicine practices. Ann Intern Med. 1995;123(10):737-746. [pmid: 7574191].
21 Dearwater SR, Coben JH, Campbell JC, et al. Prevalence of intimate partner abuse in women treated at community hospital emergency departments. JAMA. 1998;280(5):433-438. [pmid: 9701078].
22 Jones AS, Gielen AC, Campbell JC, et al. Annual and lifetime prevalence of partner abuse in a sample of female HMO enrollees. Womens Health Issues. 1999;9(6):295-305.
23 Karus D, Siegel K, Raveis VH. Psychosocial adjustment of women to living with HIV/AIDS. AIDS Behav. 1999;3(4).
24 Coker AL, Smith PH, Bethea L, King MR, McKeown RE. Physical health consequences of physical and psychological intimate partner violence. Arch Fam Med. 2000;9(5):451-457. [pmid: 10810951].
25 Richardson J, Coid J, Petruckevitch A, Chung WS, Moorey S, Feder G. Identifying domestic violence: cross sectional study in primary care. BMJ. 2002;324(7332):274. [pmid: 11823360]. [pmcid: 65060].
26 McFarlane J, Parker B, Soeken K, Bullock L. Assessing for abuse during pregnancy. Severity and frequency of injuries and associated entry into prenatal care. JAMA. 1992;267(23):3176-3178. [pmid: 1593739].
27 Silverman JG, Raj A, Mucci LA, Hathaway JE. Dating violence against adolescent girls and associated substance use, unhealthy weight control, sexual risk behavior, pregnancy, and suicidality. JAMA. 2001;286(5):572-579. [pmid: 11476659].
28 Ernst AA, Weiss SJ. Intimate partner violence from the emergency medicine perspective. Women Health. 2002;35(23):71-81. [pmid: 12201511].
29 Muelleman RL, Lenaghan PA, Pakieser RA. Battered women: injury locations and types. Ann Emerg Med. 1996;28(5):486-492. [pmid: 8909268].
30 Prevalence, Incidence, and Consequences of Violence Against Women: Findings from the National Violence Against Women Survey: National Institute of Justice and Centers for Disease Control and Prevention; 1998.
31 Rodriguez MA, Sheldon WR, Bauer HM, Perez-Stable EJ. The factors associated with disclosure of intimate partner abuse to clinicians. J Fam Pract. 2001;50(4):338-344. [pmid: 11309220].
32 Kantor GK, Straus MA. Substance abuse as a precipitant of wife abuse victimizations. Am J Drug Alcohol Abuse. 1989;15(2):173-189. [pmid: 2729225].
33 Weinbaum Z, Stratton TL, Chavez G, Motylewski-Link C, Barrera N, Courtney JG. Female victims of intimate partner physical domestic violence (IPP-DV), California 1998. Am J Prev Med. 2001;21(4 Nov 2001):313-319. [pmid: 11701303].
34 Bauer HM, Rodriguez MA, Perez-Stable EJ. Prevalence and determinants of intimate partner abuse among public hospital primary care patients. J Gen Intern Med. 2000;15(11):811-817. [pmid: 11119174]. [pmcid: 1495615].
35 Wasson JH, Jette AM, Anderson J, Johnson DJ, Nelson EC, Kilo CM. Routine, single-item screening to identify abusive relationships in women. J Fam Pract. 2000;49(11):1017-1022. [pmid: 11093568].
36 Harwell TS, Spence MR. Population surveillance for physical violence among adult men and women, Montana 1998. Am J Prev Med. 2000;19(4) Nov 2000):US, www.
37 Tollestrup K, Sklar D, Frost FJ, et al. Health indicators and intimate partner violence among women who are members of a managed care organization. Prev Med. 1999;29(5):431-440. [pmid: 10564635].
38 Kershner M, Long D, Anderson JE. Abuse against women in rural Minnesota. Public Health Nurs. 1998;15(6):422-431. [pmid: 9874924].
39 Coker AL, Smith PH, McKeown RE, King MJ. Frequency and correlates of intimate partner violence by type: Physical, sexual, and psychological battering. Am J Public Health. 2000;90(4):553-559. [pmid: 10754969]. [pmcid: 1446198].
40 Rural health-care providers' attitudes, practices, and training experience regarding intimate partner violence—West Virginia, March 1997. MMWR Morb Mortal Wkly Rep. 1998;47(32):670–673.
41 Bullock L, McFarlane J, Bateman LH, Miller V. The prevalence and characteristics of battered women in a primary care setting. Nurse Pract. 1989;14(6):47, 50, 53–46.
42 Zachary MJ, Mulvihill MN, Burton WB, Goldfrank LR. Domestic abuse in the emergency department: can a risk profile be defined?. Acad Emerg Med. 2001;8(8):796-803. [pmid: 11483454].
43 Coid J, Petruckevitch A, Feder G, Chung W, Richardson J, Moorey S. Relation between childhood sexual and physical abuse and risk of revictimisation in women: a cross-sectional survey. Lancet. 2001;358(9280):450-454. [pmid: 11513908].
44 Roberts SJ. The sequelae of childhood sexual abuse: a primary care focus for adult female survivors. Nurse Pract. 1996;21(12 Pt 1):42, 45, 49–52.
45 Tatara T, Kuzmeskus-Blumerman, L., Duckhorn, E., Bivens, L., Thomas, C., Gertig, J., Jay, K., Hartley, A., Rust, K., Croos, J. The National Elder Abuse Incidence Study (NEAIS); Final Report: By The National Center on Elder Abuse at the American Public Human Services Association in Collaboration with Westat, Inc. for the Administration for Children and Families and The Administration on Aging in the U.S. Department of Health and Human Services; 1998.
46 Pillemer K, Finkelhor D. The prevalence of elder abuse: A random sample survey. Gerontologist. 1988;28(1):51-57. [pmid: 3342992].
47 Elder abuse and neglect. Council on Scientific Affairs. JAMA. 1987;257(7):966–971.
48 Lachs MS, Williams C, O'Brien S, Hurst L, Horwitz R. Risk factors for reported elder abuse and neglect: a nine-year observational cohort study. Gerontologist. 1997;37(4):469-474. [pmid: 9279035].
49 Hwalek MA, Neale AV, Goodrich CS, Quinn K. The association of elder abuse and substance abuse in the Illinois Elder Abuse System. Gerontologist. 1996;36(5):694-700. [pmid: 8942114].
50 Godkin MA, Wolf RS, Pillemer KA. A case-comparison analysis of elder abuse and neglect. Int J Aging Hum Dev. 1989;28(3):207-225. [pmid: 2707901].
51 Dyer CB, Pavlik VN, Murphy KP, Hyman DJ. The high prevalence of depression and dementia in elder abuse or neglect. J Am Geriatr Soc. 2000;48(2):205-208. [pmid: 10682951].
52 Coyne AC, Reichman WE, Berbig LJ. The relationship between dementia and elder abuse. Am J Psychiatry. 1993;150(4):643-646. [pmid: 8465884].
53 Reay AM, Browne KD. Risk factor characteristics in carers who physically abuse or neglect their elderly dependants. Aging Ment Health. 2001;5(1):56-62. [pmid: 11513015].
54 Coyle BS, Wolan DL, Van Horn AS. The prevalence of physical and sexual abuse in women veterans seeking care at a Veterans Affairs Medical Center. Mil Med. 1996;161(10):588-593. [pmid: 8918119].
55 Dube SR, Anda RF, Felitti VJ, Chapman DP, Williamson DF, Giles WH. Childhood abuse, household dysfunction, and the risk of attempted suicide throughout the life span: findings from the Adverse Childhood Experiences Study. JAMA. 2001;286(24):3089-3096. [pmid: 11754674].
56 Anda RF, Whitfield CL, Felitti VJ, et al. Adverse childhood experiences, alcoholic parents, and later risk of alcoholism and depression. Psychiatr Serv. 2002;53(8):1001-1009. [pmid: 12161676].
57 Diaz A, Simantov E, Rickert VI. Effect of abuse on health: results of a national survey. Arch Pediatr Adolesc Med. 2002;156(8):811-817. [pmid: 12144373].
58 Osofsky JD, Wewers S, Hann DM, Fich AC. Chronic community violence: what is happening to our children?. Psychiatry. 1993;56:36-45. [pmid: 8488211].
59 Shakoor BH, Chalmers D. Co-victimization of African-American children who witness violence: effects on cognitive, emotional and behavioral development. J Natl Med Assoc. 1991;83:233-238. [pmid: 2038083]. [pmcid: 2627039].
60 Lansford JE, Dodge KA, Pettit GS, Bates JE, Crozier J, Kaplow J. A 12-year prospective study of the long-term effects of early child physical maltreatment on psychological, behavioral, and academic problems in adolescence. Arch Pediatr Adolesc Med. 2002;156(8):824-830. [pmid: 12144375].
61 Campbell JC, Lewandowski LA. Mental and physical health effects of intimate partner violence on women and children. Psychiatr Clin North Am. 1997;20(2):353-374. [pmid: 9196919].
62 Campbell J, Jones AS, Dienemann J, et al. Intimate partner violence and physical health consequences. Arch Intern Med. 2002;162(10):1157-1163. [pmid: 12020187].
63 Coker AL, Smith PH, Thompson MP, McKeown RE, Bethea L, Davis KE. Social support protects against the negative effects of partner violence on mental health. J Womens Health Gender-Based Med. 2002;11(5):465-476.
64 Maxfield M, Widom C. The cycle of violence, revisited 6 years later. Arch Adolesc Med. 1996;50:390-395.
65 Garbarino J, Kostelny DN. What children can tell us about living in danger. Am Psychol. 1991;46:376-383. [pmid: 2048796].
66 Durant RH, Pendergrast RA, Cadenhead C. Exposure to violence and victimization and fighting behavior by black urban adolescents. J Adolesc Health. 1994;15:311-318. [pmid: 7918504].
67 Diagnostic and Treatment Guidelines Concerning Child Abuse and Neglect. American Medical Association (AMA) Council on Scientific Affair; 1984.
68 Diagnostic and Treatment Guidelines on Elder Abuse and Neglect. American Medical Association Council on Scientific Affairs; 1992.
69 Child Abuse and Neglect: State Statutes Series, Current Trends in Child Maltreatment Reporting Laws. Washington, DC: U.S. Department of Health and Human Services, Administration for Children and Families; 1999.
70 Accreditation Manual for Hospitals. Vol 1-Standards. Joint Commission on Accreditation of Healthcare Organizations. Oakbrook Terrace, IL: JCAHO; 1992.
71 Cole TB. Is domestic violence screening helpful?. JAMA. 2000;284(5):551-553. [pmid: 10918685].
72 Ramsay J, Richardson J, Carter YH, Davidson LL, Feder G. Should health professionals screen women for domestic violence? Systematic review. BMJ. 2002;325(7359):314-326. [pmid: 12169509]. [pmcid: 117773].
73 Borowsky IW, Ireland M. Parental screening for intimate partner violence by pediatricians and family physicians. Pediatrics. 2002;110(3):509-516. [pmid: 12205252].
74 Chamberlain L, Perham-Hester KA. Physicians' screening practices for female partner abuse during prenatal visits. Matern Child Health Jl. 2000;4(2):141-148.
75 Chamberlain L, Perham-Hester KA. The impact of perceived barriers on primary care physicians' screening practices for female partner abuse. Women Health. 2002;35(23):55-69. [pmid: 12201510].
76 Glass N, Dearwater S, Campbell J. Intimate partner violence screening and intervention: data from eleven Pennsylvania and California community hospital emergency departments. J Emerg Nurs. 2001;27(2):141-149. [pmid: 11275861].
77 Rodriguez MA, Bauer HM, McLoughlin E, Grumbach K. Screening and intervention for intimate partner abuse: practices and attitudes of primary care physicians. JAMA. 1999;282(5):468-474. [pmid: 10442663].
78 Erickson MJ, Hill TD, Siegel RM. Barriers to domestic violence screening in the pediatric setting. Pediatrics. 2001;108(1):98-102. [pmid: 11433060].
79 U.S. Preventive Services Task Force. Guide to clinical preventive services, 2nd ed. Baltimore: Williams & Wilkins, 1996.
80 Bilukha O, Hahn R, et al. A Review of the effectiveness of early childhood home visitation for the prevention of violence: U.S. Task Force on Community Prevention Services (TFCPS); 2002.
81 MacMillan HL, Canadian Task Force on Preventive Health C. Preventive health care, 2000 update: prevention of child maltreatment. Can Med Assoc J. 2000;163(11):1451-1458. [pmid: 11192650]. [pmcid: 80412].
82 Chalk R, King PA. Violence In Families: Assessing Prevention and Treatment Programs. Washington, D.C.: Commission on Behavioral and Social Sciences and Education National Research Council and Institute of Medicine; 1998.
83 Harris RP, Helfand M, Woolf SH, et al. Methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
84 Murphy S, Orkow B, Nicola RM. Prenatal prediction of child abuse and neglect: a prospective study. Child Abuse Negl. 1985;9(2):225-235. [pmid: 4005663].
85 Stevens-Simon C, Barrett J. A comparison of the psychological resources of adolescents at low and high risk of mistreating their children. J Pediatr Health Care. 2001;15(6):299-303. [pmid: 11717686].
86 Korfmacher J. The Kempe Family Stress Inventory: a review. Child Abuse Negl. 2000;24(1):129-140. [pmid: 10660015].
87 Duggan A, Windham A, McFarlane E, et al. Hawaii's healthy start program of home visiting for at-risk families: evaluation of family identification, family engagement, and service delivery. Pediatrics. 2000;105(1 Pt 3):250-259. [pmid: 10617732].
88 Katzev A, Pratt C, Henderson T, McGuigan W. Oregon's Healthy Start effort: 1997-98 status report. Corvalis, OR: Oregon State University Family Policy Program; 1999.
89 Brayden R, ALtemeier W. A prospective study of secondary prevention of child maltreatment. J Pediatr. 1993;122:511-516. [pmid: 8463893].
90 Anderson CL. The parenting profile assessment: screening for child abuse. Appl Nurs Res. 1993;6(1):31-38. [pmid: 8439176].
91 Leventhal JM, Pew MC, Berg AT, Garber RB. Use of health services by children who were identified during the postpartum period as being at high risk of child abuse or neglect. Pediatrics. 1996;97(3):331-335. [pmid: 8604265].
92 Olds DL, Henderson CR Jr, Chamberlin R, Tatelbaum R. Preventing child abuse and neglect: a randomized trial of nurse home visitation. Pediatrics. 1986;78(1):65-78. [pmid: 2425334].
93 Olds DL, Henderson CR, Kitzman H. Does prenatal and infancy nurse home visitation have enduring effects on qualities of parental caregiving and child health at 25 to 50 months of life?. Pediatrics. 1994;93(1):89-98. [pmid: 8265329].
94 Olds D, Henderson CR, Kitzman H, Cole R. Effects of prenatal and infancy nurse home visitation on surveillance of child maltreatment. Pediatrics. 1995;95(3):365-372. [pmid: 7862474].
95 Olds DL, Eckenrode J, Henderson CR, et al. Long-term effects of home visitation on maternal life course and child abuse and neglect. Fifteen-year follow-up of a randomized trial. JAMA. 1997;278(8):637-643. [pmid: 9272895].
96 Eckenrode J, Ganzel B, Henderson CR, et al. Preventing child abuse and neglect with a program of nurse home visitation: the limiting effects of domestic violence. JAMA. 2000;284(11):1385-1391. [pmid: 10989400].
97 Barth RP. An experimental evaluation of in-home child abuse prevention services. Child Abuse Negl. 1991;15(4):363-375. [pmid: 1959070].
98 Marcenko MO, Spence M. Home visitation services for at-risk pregnant and postpartum women: a randomized trial. Am J Orthopsychiatry. 1994;64(3):468-478. [pmid: 7977669].
99 Black MM, Nair P, Kight C, Wachtel R, Roby P, Schuler M. Parenting and early development among children of drug-abusing women: effects of home intervention. Pediatrics. 1994 Oct;94(4 pt 1).
100 Siegel E, Bauman KE, Schaefer ES, Saunders MM, Ingram DD. Hospital and home support during infancy: impact on maternal attachment, child abuse and neglect, and health care utilization. Pediatrics. 1980;66(2):183-190. [pmid: 7402803].
101 Kitzman H, Olds D, Henderson C. Effect of prenatal and infancy home visitation by nurses on pregnancy outcomes, childhood injuries, and repeated childbearing: a randomized controlled trial. JAMA. 1997;278:644-652. [pmid: 9272896].
102 Brooten D, Kumar S. A randomized controlled trial of early hospital discharge and home follow-up of very-low-birth weight infants. N Engl J Med. 1986;315:934-939. [pmid: 3531852].
103 Gray JD, Cutler CA, Dean JG, Kempe CH. Prediction and prevention of child abuse. Semin Perinatol. 1979;3(1):85-90. [pmid: 482971].
104 Dawson P, Van Doorninck WJ, Robinson JL. Effects of home-based, informal social support on child health. Dev Behav Pediatr. 1989;10(2):63-67.
105 Cerny JE, Inouye J. Utilizing the child abuse potential inventory in a community health nursing prevention program for child abuse. J Community Health Nurs. 2001;18(4):199-211. [pmid: 11775554].
106 Flynn L. The adolescent parenting program: improving outcomes through mentorship. Public Health Nurs. 1999;16:182-189. [pmid: 10388335].
107 Coker AL, Pope BO, Smith PH, Sanderson M, Hussey JR. Assessment of clinical partner violence screening tools. J Am Med Womens Assoc. 2001;56(1):19-23. [pmid: 11202067].
108 Brown JB, Lent B, Schmidt G, Sas G. Application of the Woman Abuse Screening Tool (WAST) and WAST-short in the family practice setting. J Fam Pract. 2000;49(10):896-903. [pmid: 11052161].
109 Sherin KM, Sinacore JM, Li XQ, Zitter RE, Shakil A. HITS: a short domestic violence screening tool for use in a family practice setting. Fam Med. 1998;30(7):508-512. [pmid: 9669164].
110 Feldhaus KM, Koziol-McLain J, Amsbury HL, Norton IM, Lowenstein SR, Abbott JT. Accuracy of 3 brief screening questions for detecting partner violence in the emergency department. JAMA. 1997;277(17):1357-1361. [pmid: 9134940].
111 Ernst AA, Weiss SJ, Cham E, Marquez M. Comparison of three instruments for assessing ongoing intimate partner violence. Med Sci Monitor. 2002;8(3):CR197-201.
112 Morrison LJ, Allan R, Grunfeld A. Improving the emergency department detection rate of domestic violence using direct questioning. J Emerg Med. 2000;19(2):117-124. [pmid: 10903457].
113 Canterino JC, VanHorn LG, Harrigan JT, Ananth CV, Vintzileos AM. Domestic abuse in pregnancy: a comparison of a self-completed domestic abuse questionnaire with a directed interview. Am J Obstet Gynecol. 1999;181:1049-1051. [pmid: 10561616].
114 Norton LB, Peipert JF, Zierler S, Lima B, Hume L. Battering in pregnancy: an assessment of two screening methods. Obstet Gynecol. 1995;85(3):321-325. [pmid: 7862365].
115 Pan HS, Ehrensaft MK, Heyman RE, O'Leary KD, Schwartz R. Evaluating domestic partner abuse in a family practice clinic. Fam Med. 1997;29(7):492-495. [pmid: 9232411].
116 Smith M, Martin F. Domestic violence: recognition, intervention, and prevention. Medsurg Nurs. 1995;4(1):21-25. [pmid: 7874217].
117 Furbee PM, Sikora R, Williams JM, Derk SJ. Comparison of domestic violence screening methods: a pilot study. Ann Emerg Med. 1998;31(4):495-501. [pmid: 9546020].
118 McFarlane J, Christoffel K, Bateman L, Miller V, Bullock L. Assessing for abuse: self-report versus nurse interview. Public Health Nurs. 1991;8(4):245-250. [pmid: 1766908].
119 McFarlane J, Soeken K, Wiist W. An evaluation of interventions to decrease intimate partner violence to pregnant women. Public Health Nurs. 2000;17(6):443-451. [pmid: 11115142].
120 Parker B, McFarlane J, Soeken K, Silva C, Reel S. Testing an intervention to prevent further abuse to pregnant women. Res Nurs Health. 1999;22(1):59-66. [pmid: 9928964].
121 Reis M, Nahmiash D. Validation of the Caregiver Abuse Screen (CASE). Can J Aging. 1995;14(2):45-60.
122 Neale AV, Hwalek Melanie A, Scott Richard O, Sengstock Mary C, Stahl C. Validation of the Hwalek-Sengstock Elder Abuse Screening Test. J Appl Gerontol. Dec. 1991;10(4):406-418.
123 Moody LE, Voss A, Lengacher CA. Assessing abuse among the elderly living in public housing. J Nurs Meas. 2000;8(1):61-70. [pmid: 11026166].
124 Webster J, Stratigos SM, Grimes KM. Women's responses to screening for domestic violence in a health-care setting. Midwifery. 2001;17(4):289-294. [pmid: 11749061].
125 Stenson K, Saarinen H, Heimer G, Sidenvall B. Women's attitudes to being asked about exposure to violence. Midwifery. 2001;17(1):2-10. [pmid: 11207100].
126 Dowd MD, Kennedy C, Knapp JF, Stallbaumer-Rouyer J. Mothers' and health care providers' perspectives on screening for intimate partner violence in a pediatric emergency department. Arch Pediatr Adolesc Med. 2002;156(8):794-799. [pmid: 12144370].
127 Sachs CJ, Koziol-McLain J, Glass N, Webster D, Campbell J. A population-based survey assessing support for mandatory domestic violence reporting by health care personnel. Women Health. 2002;35(23):121-133. [pmid: 12201503].
128 Gielen AC, O'Campo PJ, Campbell JC, et al. Women's opinions about domestic violence screening and mandatory reporting. Am J Prev Med. 2000;19(4):279-285. [pmid: 11064232].
129 Paavilainen E, Merikanto J, Astedt-Kurki P, Laippala P, Tammentie T, Paunonen-Ilmonen M. Identification of child maltreatment while caring for them in a university hospital. Int J Nurs Stud. 2002;39(3):287-294. [pmid: 11864652].
130 Heger A, Ticson L, Velasquez O, Bernier R. Children referred for possible sexual abuse: medical findings in 2384 children. Child Abuse Negl. 2002;26(67):645-659. [pmid: 12201160].
131 Johnson CF. Inflicted injury versus accidental injury. [Review] [87 refs]. Pediatr Clin North Am. 1990;37(4):791-814. [pmid: 2199916].
132 McIntyre LM, Butterfield MI, Nanda K, et al. Validation of a Trauma Questionnaire in veteran women. J Gen Intern Med. 1999;14(3):186-189. [pmid: 10203625]. [pmcid: 1496546].
133 English DJ. The extent and consequences of child maltreatment. Future Child. 1998;8(1):39-53. [pmid: 9675999].
134 Voelker R. Elder abuse and neglect a new research topic. JAMA. 2002;288(18):2254-2256. [pmid: 12425686].
135 Olds DL, Kitzman H. Can home visitation improve the health of women and children at environmental risk?. Pediatrics. 1990;86(1):108-116. [pmid: 2193300].
136 Fogarty CT, Brown JB. Screening for abuse in Spanish-speaking women. J Am Board Fam Pract. 2002;15(2):101-111. [pmid: 12002193].
137 Agency for Healthcare Research and Quality. Evaluating domestic violence programs. Rockville, MD: Agency for Healthcare Research and Quality; September 2002; http://www.ahrq.gov/research/domesticviol.
138 Brewster AL, Milner JS, Mollerstrom WW, Saha BT, Harris N. Evaluation of spouse abuse treatment: description and evaluation of the Air Force Family Advocacy Programs for spouse physical abuse. Mil Med. 2002;167(6):464-469. [pmid: 12099080].
139 Wolfe DA, Wekerle C. Treatment strategies for child physical abuse and neglect: A critical progress report. Clin Psychol Rev. 1993;13:473-500.
140 Moore EAG, Gogerty PL. A twelve-year follow-up study of maltreated and at-risk children who received early therapeutic child care. Child Mal: J Am Prof Abuse Child. 1998;3(1):3-16.