# Acknowledgments

This systematic evidence review was prepared for the Agency for Healthcare Research and Quality (contract #290-97-0018, task order no. 2) to be used by the U.S. Preventive Services Task Force. Yasmin McInerney MD was a fellow in the Veteran's Affairs special fellowship in Health Issues of women veterans when this work was conducted. Task Force members Jonathan Klein, MD, MPH and Janet Allen, PhD, RN, served as liaisons. Oregon Health & Science University, Evidence-based Practice Center staff who contributed to this project included Kathryn Krages, Miranda Norbraten, Susan Wingenfeld, and Patty Davies, librarian.