# Future Research

There are many gaps in the evidence for screening for family and intimate partner violence in the primary care setting. Future research could address the following issues:

- Definitions and measures of abuse and neglect need to be standardized across studies. Definitions range from broad to narrow and sometimes include emotional and sexual abuse, while reports of abuse range from unsubstantiated self-report to state agency verified reports.^133^ Measures of severity and chronicity need to be refined. The development and application of standardized instruments and evaluation tools would allow a more uniform approach and opportunities to combine and compare data from various settings.
- Lack of instruments and interventions for elder abuse and neglect necessitate establishment of a research agenda to develop, test, and implement effective procedures.^134^
- Studies need to consider the influence of observer or surveillance bias.^44, ^ ^80, ^ ^94^ In studies of child abuse, families are selected for interventions because of their potential for abuse and/or neglect. Therefore, families in the intervention group can and do show ‘dysfunctional parenting’ behavior when observed by home visitors.^103, ^ ^104^ Because the control group exhibiting the abusive or neglectful behaviors will potentially never be observed by the home visitor, reports in the intervention vs. control group may be distorted.
- Interventions are dissimilar between studies, and often inadequately described. Future research could define interventions in a more complete, standardized way. Experts in the field consider the most effective interventions for early child abuse prevention those that employ nurses who begin visiting during pregnancy, visit frequently, and address behavioral and psychological factors that influence maternal and child outcomes.^135^ Programs that deviate from this model may have different results.
- Screening and intervention studies are currently confined to high-risk populations. Broader application to the general population would demonstrate if results are generalizable.
- Studies of special populations, such as cultural groups, military families, etc., are needed to address issues unique to them. Instruments require validation in languages other than English.^136^
- Existing screening instruments require more testing and validation in various medical settings, and modification of those that are too long or complex for medical practice.
- The feasibility of screening procedures and interventions in the primary care setting requires evaluation (i.e., costs, time, resources, clinician consistency, patient compliance). Strategies enlisting health systems and community programs and evaluations of them are needed.^137^
- Further studies of barriers to screening would identify areas for improvement. Although most women believe routine screening in a health care setting is acceptable to them, most clinician's voice reluctance to screen.
- More efforts in the development of instruments and procedures to be used with children age 5 to 18 years old are needed since virtually all existing instruments focus on very young children and involve parents.
- More research is required to better understand pregnancy-related violence in areas such as the course of violence during the pregnancy and postpartum periods, health implications for the mother and child, the role of violence on reproductive decision making, determination of what screening and intervention strategies are most effective for this population.
- Studies of the effectiveness of treatment programs for abused victims as well as for perpetrators^138^–^140^ would provide needed evidence that identification and intervention can lead to improved health outcomes. These outcomes should include not only measures of reduced violence, but also improved quality of life, mental health, social support, self-esteem, productivity, and others.