# Conclusions

A summary of the types and quality of evidence for each key question is described in Table 7. We identified no studies meeting eligibility criteria that directly addressed the effectiveness of screening in a health care setting in reducing harm and premature death and disability, or the adverse effects of screening and interventions.

Table 7 Summary of Evidence

| | Quality of Evidence**
Key Questions | Evidence Codes* | Internal Validity | External Validity
Arrow 1: Does screening reduce harm and premature death and disability? | None available
Arrow 2: How well does screening identify current harm or risk of harm?
Children | II-1 | Poor-good: Instruments were developed mostly for pregnant women; few instruments evaluated; no studies involving other methods of screening were identified. | None screen children directly; all but one focus on pregnant women.
Women | II-1 | Poor-good: Many instruments tested in primary care settings and indicate fair-good correlation with longer instruments; no studies follow women longitudinally. | Several brief instruments tested using a variety of settings and populations.
Elderly adults | II-1 | Fair: 1 designed for caregivers, 2 for elderly adults; results correlate with longer instruments. | Few instruments studied, none in healthcare settings.
Arrow 3: What are the adverse effects of screening? | None available
Arrow 4: How well do interventions reduce harm?
Children | I, II-1, II-2 | Poor-good: A trial of home nurse visits during and after pregnancy indicated reduced violence measures up to 15 years after intervention; other studies of modified versions of this intervention report improved outcomes related to violence. | Interventions are confined to pre and postnatal periods and focus on newborns and infants; populations are defined as high risk by various eligibility criteria.
Women | I, II-1 | Fair: 2 small trials suggest benefit using self-reported outcomes. | Studied in small populations of pregnant women only.
Elderly adults | None available
Arrow 5: What are the adverse effects of intervention? | None available

* Study Design Categories

I: Randomized, controlled trials

II-1: Controlled trials without randomization

II-2: Cohort or case-control analytic studies

II-3: Multiple time series, dramatic uncontrolled experiments

III: Opinions of respected authorities, descriptive epidemiology

** Described in Appendix 2 and Harris, 2001.

Our literature search and review identified several studies about screening instruments for women, a limited number about screening parents for child abuse, few of screening elderly adults for abuse, a study about screening newborns for potential abuse using clinician observation, and a study determining concern for abuse by caregivers of elderly adults.

All instruments designed to screen for child abuse and neglect were directed to parents, particularly pregnant women. These had fairly high sensitivity but low specificity when administered in the study populations, particularly when provided in a 2-step method such as the Hawaii Risk Indicators Screening Tool followed by the Kempe Family Stress Inventory. However, these have not been widely tested in other populations. Several brief instruments designed to identify women with intimate partner violence in primary care settings compared well to longer previously-validated instruments. Studies indicated that self-administered questionnaires elicited more positive responses than interviewer-administered questionnaires in emergency department settings, but the opposite was true in a Planned Parenthood clinic. We found few studies of screening for elder abuse and they were conducted outside of health care settings.

Studies of interventions for prevention of child abuse focused on the prenatal, postpartum, and early childhood periods, corresponding to times of increased vulnerability and health care need for both women and children. A randomized controlled trial with 15 years follow-up indicated that nurse home visits during the prenatal period and for 2-years postpartum for low-income women can improve short-term and long-term abuse and neglect outcomes for children.^92^–^96^ Several subsequent trials utilizing nurse home visits for varying lengths of time and with differing program components for pregnant and postpartum women supported these findings, although the outcomes in these studies were short-term measures of abuse-related factors. Both the U.S. Task Force on Community Preventive Services^80^ and the Canadian Task Force on Preventive Health Care^81^ have documented the benefits of early home visitation, and recommended this service as a component in a comprehensive health care delivery system for pregnant or postpartum women. Whether the home visit model can be adapted more broadly is not known.

Studies of interventions initiated in the primary care setting with health outcomes for children of other ages, women who are not pregnant, and elderly adults are lacking. A systematic review of health care interventions for intimate partner violence found very few studies with other types of outcomes.^72^ Although referrals to community resources, shelters, social workers, and police were often increased when abused women were identified, it is not known if these interventions improved their experiences with violence or health outcomes.^72^ These studies were found to have weak study designs and provided inconsistent results.

Although the literature on family and intimate partner violence is extensive, there are few studies providing data on its detection and management to guide clinicians. Determination of performance characteristics of screening instruments, such as sensitivity and specificity, is lacking largely because of the difficulty in comparing screening scores with actual episodes of abuse. For children, mandatory reporting requires that documentation of abuse exists, but reported abuse likely captures only a fraction of all cases. In a recent survey of nurses and physicians, 71% of respondents rated the identification of maltreatment as ‘rather difficult or difficult.’^129^ Work pressure, unfamiliarity, and awkwardness were cited as barriers.

Existing instruments to detect child abuse are not designed for direct administration to the child, missing opportunities to screen older children in the context of usual health care. Screening for physical, emotional and/or sexual child abuse in the primary care setting can involve a variety of techniques including physical examination as well as screening questionnaires. History from the child has been stated as the most important diagnostic feature in determining child sexual abuse.^130^ Findings in a routine physical examination suggestive of abuse and/or neglect, such as burns, bruises, and repeated suspicious traumatic injury, have been described.^79, ^ ^131^ Many professional medical organizations including the American Academy of Physicians, American Academy of Pediatrics, the American Medical Association, and the American Academy of Family Practitioners continue to recommend that physicians remain alert for the signs and symptoms of child abuse and neglect in the medical visit.

For women, self-reported intimate partner abuse may be a useful outcome, although, the accuracy of self-report may vary widely. The effectiveness of specific screening methods and interventions could depend on setting, delivery, culture, and population. Screening for past abuse could be useful in managing chronic conditions related to abuse such as post-traumatic stress disorder, although this has yet to be demonstrated.^132^

Self-reported abuse by the elderly may be compromised by cognitive impairment and overshadowed by other medical problems addressed in primary care clinics. Few instruments have been developed for the elderly and none have been widely validated. As with assessing child abuse, a more comprehensive approach including physical examination, caretaker and home evaluations, as well as direct questioning may be most effective.