# Results

## Child Abuse and Neglect

### Screening

1,808 abstracts were captured in searches of MEDLINE, CINAHL, and Health & Psychosocial Instruments (searches provided in Appendix 1). Sixty-five full text articles were retrieved for further review; 6 studies met eligibility criteria.

Studies meeting eligibility criteria utilized self-administered questionnaires, sometimes in conjunction with interviews and review of medical records, clinical staff-directed interviews, and clinical observation to identify families with current harm or risk for harm. All studies primarily assessed parents, rather than children directly, and none utilized specific physical examination protocols for screening. Instruments included in these studies are described in Appendix 3.

Self-administered questionnaires. The Kempe Family Stress Inventory (KFI) ^84^ was used in 3 studies meeting eligibility criteria (Table 1). Study populations included predominantly young, single women with low socioeconomic indicators. A retrospective cohort study in Denver included 262 adolescent parents in a university hospital maternity program.^85^ Cases of child abuse and neglect were recorded by medical staff. As part of a larger battery of measures, families completed the 10-item KFI including questions about stressful events, parent behavior, and other risk factors associated with child abuse and neglect. Scores on the KFI were the only statistically significant predictors of maltreatment at 1 year (RR 8.41, CI 5.77–10.01; p=0.0009) and at 2 years postpartum (RR 5.19, CI 1.99–13.60; p=0.004). In addition, families identified with high risk scores on the KFI were more likely to initiate clinic visits for their children during the first year (p<0.0001) and admit their children to the hospital during the first 6 months (p=0.06) than low risk mothers.

Table 1 Studies of Child Abuse and Neglect Screening Instruments

Author, Year | N | Population/Setting | Instruments | Results | Quality Rating/ Limitations
Self-Administered Questionnaires
CCAPR, 1996a, b; Korfmacher, 2000^86^; Duggan, 2000^87^ | 287 | Pregnant women at hospital obstetric clinics in 6 counties in Oahu (Hawaii Healthy Start) Mean age 23 65% poor; 89% multi-cultural; 40% poor maternal mental health; 45% domestic violence in the home; 30% parental substance use; 28% no high school diploma | 2 step screening:; 1) 15 item Hawaii Risk Indicators Screening Tool (medical record or interview); 2) Kempe Family Stress Inventory (KFI) | 89% sensitivity | FAIR: No abuse outcomes, high attrition
| | | | 28% specificity with high scores on the Child Abuse Potential (CAP) inventory
Stevens -Simon, 2001^85^ | 262 | Adolescents (13–19 yrs old) in a maternity program at the University of Colorado Hospital in Denver | Kempe Family Stress Inventory (KFI) | At 1 & 2 years, the KFI was the only significant predictor of maltreatment using multiple outcome measures (RR 8.41, 5.77–10, p=0.0009; RR 5.19,1.99–13.60, p=0.004). | GOOD-FAIR: Differential loss to follow up
| | 32% African American
| | 22% Hispanic
| | 92% Medicaid recipients
| | 94% unmarried
Katzev, 1997^88^ | 2,870 | At risk pregnant women from 12 counties in Oregon (Healthy Families) | 2 step screening:; 1) 15 item Hawaii Risk Indicators Screening Tool (medical record or interview); 2) If positive then, Kempe Family Stress Inventory (KFI) (score >25 is high stress) | 1,350 were given the KFI. Score was highly correlated with maltreatment rates (per 1000 children): 7 for low risk scores, 18 moderate, 45 high, and 172 severe. Sensitivity 97%, specificity 21% for scores in high-severe risk range. | FAIR-POOR: Many confirmed reports were made by home visitors to high-risk homes (surveillance bias)
| | 72% single parents
| | 68% with history of child abuse or neglect
| | 57% <high school education
| | 37% history of substance abuse
| | 29% 17 yrs or younger
Administered by Clinical Staff
Anderson, 1993^90^ | 185 | Abusive and nonabusive mothers obtained by a national sample of female nurses contacted through advertising and a mailing list | Parenting Profile Assessment (PPA), 21-item nurse interview for primary care setting | 75% sensitivity | POOR: Only self-report of abuse by mothers, no actual abuse measured or verified, small sample with only 15 self-reported abusers
| | | | 86% specificity for self reported abuse;
| | | | Most sensitive to high stress, poor marital relationships.
Brayden, 1993^89^ | 1,089 | Pregnant women receiving prenatal care at Metropolitan Nashville General Hospital, TN | Maternal History Interview-2: open-ended questions and subscales including issues of parenting skills, personality, discipline philosophy, life stress, and others. | The Maternal History Inteview-2 predicted child abuse, but not neglect or sexual abuse. High risk group had 6.6% with child abuse reports compared with 2.3% of low risk (RR 3.02, CI 1.02–8.90). | FAIR: Participation was low, requires trained interviewers
| | <23 yrs old
| | 60% single
| | 68% Caucasian
| | 25% unemployed
Clinician Observation
Leventhal, 1996^91^ | 114 cases | Children at the Primary Care Center at Yale New Haven Hospital referred to the hospital's child abuse committee from the postpartum ward by clinicians. | Clinician judgment of potential child abuse or neglect based on a number of criteria including parental substance use, income, social support, previous child abuse or neglect, and parenting behavior. | After controlling for baseline variables, 1.8-fold increase in the rate of subsequent hospitalizations of the high risk children compared to others (p<0.05). | POOR: Risk criteria not fully defined or standardized
| 114 controls

A study conducted in Hawaii Healthy Start affiliated obstetrics clinics that included young, poor, pregnant women with high rates of domestic violence and substance abuse, utilized the KFI in a 2-step screening process.^86, ^ ^87^ Identification of high-risk women by initial review of medical records or interview using the 15-item Hawaii Risk Indicators Screening Tool was followed by the KFI. Results were then compared with the Child Abuse Potential (CAP) inventory, a 160-item instrument. The 2-step procedure had 89% sensitivity and 28% specificity at 6-months follow-up.

An evaluation of the Oregon Healthy Families program also used the Hawaii Risk Indicators Screening Tool to screen 2,870 pregnant women considered at risk for child abuse because of history of previous abuse or neglect, history of substance abuse, and young age, among other factors.^88^ Women who had high scores on this test (40% of cohort), were then given the KFI. Risk scores on the KFI were highly correlated with maltreatment rates (given per 1000 children): 7 with low-risk scores, 18 with moderate, 45 with high, and 172 with severe. Sensitivity was calculated at 97%, specificity 21% for scores in the high to severe range (>25 points).^86^

Clinical staff-administered questionnaires. A study of 1,089 young pregnant women receiving care at a general hospital used the Maternal History Interview (MHI-2) to determine risk for child abuse.^89^ This instrument utilizes open-ended questions and subscales to evaluate parenting skills, personality, discipline philosophy, life stress, and others. Child abuse reports for mothers identified as high risk were 6.6% compared with 2.3% for low risk (RR 3.02, CI 1.02–8.90) based on public agency reports of physical abuse, neglect, sexual assault, or mother-child separation. The MHI-2 had a positive predictive value of 6.6% and a sensitivity of 55.6% for physical abuse. This instrument did not predict neglect or sexual abuse.

The Parenting Profile Assessment (PPA) is a 21-item nurse interview designed for the primary care setting.^90^ When administered to a sample of 185 mothers who volunteered to be studied, it had 75% sensitivity and 86% specificity for child abuse based on self-reports.^90^

Other techniques: clinician observation. In a retrospective cohort study, nurses referred patients and their newborns to the hospital's child abuse committee from the postpartum unit after determining them to be at high risk for abuse based on a number of non-standardized criteria including parental substance use, income, social support, previous child abuse or neglect, and parenting behavior.^91^ Information was gathered from direct observation and medical records. When compared to the low-risk patients, the rate of subsequent hospitalizations for both medical and psychosocial reasons was significantly greater in the high-risk patients (p<0.01 and p<0.05, respectively).

Summary of child abuse and neglect screening.

- Although several screening assessment procedures are described in the literature, few studies evaluate their performances for predicting child abuse and neglect outcomes.
- Most studies of instruments screen pregnant or postpartum women; there are no studies of instruments that evaluate children directly.
- No instruments have been evaluated for feasibility in the primary care setting using measures of time, cost, or others.
- Sensitivity and specificity of instruments are poor to fair depending on the instrument and population. None has been widely tested.

### Interventions

1,748 abstracts were captured in searches of MEDLINE, CINAHL, PsycINFO, ERIC, and the Cochrane Database of Systematic Reviews and Controlled Trials (Appendix 1, Figure 3). Seventeen studies, utilizing 13 unique populations, met inclusion criteria. All studies evaluated interventions for pregnant and postpartum women and their infants. Nine randomized controlled trials were identified: one rated good quality,^92^ with 4 subsequently published follow-up studies,^93^–^96^ 6 rated fair quality,^97^–^102^ and 2 rated poor quality.^89, ^ ^103^ One poor quality quasi-experimental study,^104^ 2 fair-to-poor quality cohort studies,^88, ^ ^105^ and 1 poor quality cohort study^106^ were also identified. All studies are described in Table 2, but only the randomized controlled trials rated good or fair quality are described in the text. Results of all the studies are also summarized in Table 3.

Table 2 Studies of Child Abuse and Neglect Interventions

Author, Year | Design | N | Population/Setting | Recruitment | Inclusion Criteria | Duration | Intervention | Assessment | Results | Quality Rating
Olds, 1986^92^ (birth through 2 years) | RCT | 400 families:; 1) N=90; 2) N=94 3; 3) N=100 4; 4) N=116 | Pregnant women with no previous live births; 47% >19 years; 62% unmarried; 61% social class IV and V (semi-skilled and unskilled laborers); small, semi-rural county of 100,000 residents in New York State. | Recruited through:; a) health department ante-partum clinic; b) obstetrician's offices; c) Planned Parenthood; d) variety of other health and human services agencies. | Enrollment before 30th week of pregnancy and 85% had 1 or more of the following risk factors:; a) <19 yrs old; b) single-parent status; c) low SES | 2 yrs | 4 groups:; 1) no services; 2) free transportation to medical services; 3) same as group 2, plus a nurse home visit every 2 weeks during pregnancy; 4) same as group 3, plus nurse home visits through child's age 2. | Interviews of mothers and assessments of mothers and infants were made at 6, 10, 12, 22, and 24 months of the infant's life using Bayley Scale, Cattell Scales, & Caldwell Home Observation checklist. Outcomes were determined by review of records for the presence of abuse or neglect from the department of social services, emergency room visits, and other medical visits. | 19% of the comparison group (group 1) and 4% of the nurse visited group (group 4) were abused or neglected (p=0.07) at the 2-year assessment. Babies in the nurse visited group showed higher developmental quotient (p=0.06) and fewer visits to the emergency room for accidents and poisonings at 2 yrs of age (p=0.03). | GOOD
Olds, 1994^93^ (birth through 3 years) | RCT | 400 (minus 15–21% in each group) | 14 different states at follow-up. | Families were contacted after the study child became 3 years old. | Above | 2 yr intervention; 3 yr follow-up | Above | As stated in Olds 1986. In addition, family data and Child Protective Service (CPS) records for the first 3 years of life were reviewed. | Child abuse and neglect: no difference between groups; fewer hazards in the household (p=0.04); fewer health care encounters (emergency room) (p=0.0008); fewer injuries and ingestions (p=0.03); fewer child/behavioral/parental coping problems (p=0.006); higher level of punishment (no significance given) for group 4. | GOOD
Olds,1995^94^ (birth through 4 years) | RCT | 56 families with verified abuse from original 400 recruited | Above | The subset with verified abuse was contacted after the study child became 4 years old. | From the Olds 1986 sample, included children had state verified reports of child abuse or neglect during the first 4 yrs of the child's life. | 2 yr intervention; 4 yr follow-up | Above | As stated in Olds 1986. In addition, family data and CPS records for the first 4 years of life were reviewed. | No differences in the numbers of abuse or neglect notations coded in the CPS records, the presence of different types of maltreatment, the combination of types of maltreatment, or the extent to which children were removed from the home. Maltreated children who had nurse visits made 84% fewer visits to a physician for injuries or ingestions (p=0.01), and 38% fewer visits to the emergency department (p=0.008). | GOOD
Olds, 1997^95^ (birth through 15 years) | RCT | 324 families | Above | Families in the original study were contacted; 81% of the original sample agreed to participate. | As stated in Olds 1986. | 2 yr intervention; 15 yr follow-up | Above | The 15-year follow-up interview included a life history calendar, self-report of arrests, convictions, state and government living assistance, and drug and alcohol use. CPS and NY state arrest and conviction records were also reviewed. | Parents in the nurse visited group were perpetrators of child abuse and neglect in fewer verified reports (p<0.001). The effect was greater for women who were unmarried and had low SES (p<0.001), who also reported less impairment by alcohol or other drugs (p=0.005), fewer arrests (p<0.001), fewer convictions (p<0.008), and less jail time (p<0.001) than those in the control group. The effect of the program on the number of verified child abuse reports was especially strong for the 4–15 year period after the birth of the child (no data given). | GOOD
Eckenrode, 2000^96^ (sample from Olds 1986) | RCT | 324 families | For this analysis groups 1 and 2 were combined (N=184) and considered the comparison group. Group 4 (N=116) was considered the treatment group. Group 3 (N=24) was dropped from the analysis because it did not differ from the control group. | All 400 participants in the original study were contacted to participate. | As stated in Olds 1986. | 2 yr intervention; 15 yr follow-up | Above | At 15 year follow-up, data included mother interviews with a life-history calendar, information on life factors, Conflict Tactics Scales (a measure of partner perpetrated violence), and reports of major and minor violence. CPS records were examined and only reports of the mother as perpetrator or the study child as subject were coded. | The intervention group had fewer child maltreatment reports involving the mother as perpetrator (p=0.01), or involving the study child (p=0.04). | GOOD
Barth, 1991^97^ | RCT | control=94 | Pregnant women in CA; 45% White, 31% Latino, 17% Black, 7% other; median age 23.5 yrs; 70% had family incomes <$10,000; 90% scored above the mean on Child Abuse Potential Inventory (CAP). | Pregnant women referred by 19 public health, education, or social service professionals working in 17 different agencies or health offices. | Pregnant or postpartum women at high risk for engaging in child abuse. Two or more positive responses to a list of criteria determined eligibility for the study. | Approx. 6 months | Control group received referrals to social and health services; intervention group had home visits (ave. 11). | 2 hr initial assessment interview served as pretest for both groups. Posttest given at 6 months or when the child was 4 months old included: self report of mother's well being, CAP, community resources use scale, prenatal care, birth outcomes, child temperament, child welfare & neglect, review of medical records, and reports of child abuse & removal from home obtained from county social service records. | No statistically significant differences in numbers of families reporting child abuse or neglect, child welfare, or court-ordered in-home or out-of-home services, or other health outcomes. Control group had greater increase in unsubstantiated reports since the program (p<0.05). | FAIR
| | intervention=97
Black, 1994^99^ | RCT | 43 | Drug using pregnant women; majority single, African American, multiparus, non-high school graduates, low SES; 41% HIV; 62% history of incarceration; 16% raised in foster homes; large metropolitan teaching hospital. | Prenatal clinics at a hospital. Intervention took place at the Special Parent/Infant Care and Enrichment (SPICE) clinic. | Admitted using cocaine or heroin during pregnancy. | Birth to 30 months | All children received primary care in a multidisciplinary clinic. Treatment group received biweekly home visits provided by a nurse pre- and post-delivery up to child age 18 months. | At recruitment, each family was given the Child Abuse Potential Inventory (CAP); 3 months, Parenting Stress Index (PSI); 6 and 12 months, Bayley Scales for Infant Development; 18 months, Bayley Scales, CAP, PSI. Regular clinical visits were performed at 1, 2, 4, 6, 8, 10, 12, 15, and 18 months. At 30 months, home observation using the HOME Scale. Self reported drug use and compliance with primary care appts for mother and child were also evaluated. | At prenatal assessment, both groups showed CAP scores significantly above the norm (p<0.01). At 18 months, the intervention group had CAP scores within the norm, control group had scores above the norm (p<0.01), and there were no significant differences related to parental stress or child abuse potential. Women in the treatment group were more emotionally responsive to their children (p=0.03), had a more stimulating home environment (p=0.053), reported being drug free (r=0.53, p=0.002) and were compliant with primary care (r=0.48, p=0.016). | FAIR
Brooten, 1986^102^ | RCT | control=40 | Infants and their caretakers at the University of Pennsylvania Hospital. | Recruited from hospital nursery. | Control group infants weighed ≥ 2200 grams and met routine nursery policy before discharge. The intervention (early discharge) group infants could weigh < 2200 grams and had to meet discharge criteria. | Birth to 18 months | Intervention included nurse consultation each week while the infant was in the hospital, home visits before discharge and at one week, 1, 9, 12, and 18 months. Nurse phone contact and referral resources were available up to 8 weeks post-discharge. | Physical examinations and developmental tests were administered at one week, 1, 9, 12, and 18 months. Outcomes were determined by reports of child abuse and review of foster care records. | No differences in rehospitalizations, number of acute care visits, failure to thrive, reported child abuse, or foster care placement during the 18 month follow-up period. | FAIR
| | intervention =39
Kitzman, 1997^101^ | RCT | 1) 166; 2) 515; 3) 230; 4) 228 | 92% African American women; 64% under 18 yrs of age; 85% at or below the federal poverty level; public obstetric clinic in Memphis, TN. | Eligibility determined at the obstetric care clinic. | Pregnant women <29 weeks' gestation, no previous live births, no chronic illnesses, at least 2 sociodemographic risk characteristics (unmarried, <12 years of education, unemployment status). | Prenatal through 2 years | Interventions: 1) transportation to clinic, 2) same as group1 plus developmental screening, and referral services at 6, 12, and 24 months, 3) same as groups 1 & 2 plus 3 intensive home visitations, 4) same as groups 1, 2, & 3 plus intensive home visitation services through 2 yrs of age. | Medical records were reviewed for pregnancy outcomes, ingestions, children's injuries, and immunizations; mothers' reports of children's behavioral problems; child mental development (Bayley Scales, Child Behavior Checklist); mothers' report of demographic characteristics, beliefs about children associated with child abuse and neglect, physical punishment; and state records of use of welfare. The HOME Scale was used during home visits. | Nurse visited children had fewer health care encounters related to injuries or ingestions in the first two years, compared to comparison groups (p=0.05), with the most effect for outpatient encounters (p=0.02). By the 24th month, nurse visited women held fewer beliefs about child-rearing associated with child abuse and neglect (p=0.003). | FAIR
Marcenko, 1994^98^ | RCT | control=100 | 94% African American; 4% Hispanic; 2% white; mean age 23 years; 79% on public welfare benefits; large metropolitan inner-city hospital outpatient clinic in Philadelphia, PA. | Pregnant women were recruited by a social worker, family planning counselor, or financial assistance clerk from an inner-city hospital outpatient obstetrics clinic. Women were paid $10 for the baseline interview and $10 for a follow-up interview. | A history of at least one of the following: substance abuse, homelessness, domestic violence, psychiatric illness, incarceration, HIV infection, lack of social support. | Prenatal to 12 months postpartum (range up to 10 months in age) | The treatment group received home visits by a trained worker and had access to social worker & nurse services. | Treatment group interviews at recruitment, 6 weeks postpartum and 6 months postpartum included substance abuse (Addiction Severity Index [ASI]), self-report of CPS involvement, history of sexual or physical abuse, demographics, service use and satisfaction, social support (Norbeck Social Support Questionnaire [NSSQ]), the home environment (Home Observation for Measurement of the Environment [HOME] Inventory), psychological functioning (Brief Symptom Inventory [BSI]), and self-esteem (Rosenberg's self-esteem scale). | At birth, 9% of children in the intervention group and 4% in the control group were placed out of home by CPS (not stat sig). | FAIR
| | Intervention= 125
Siegel, 1980^100^ | RCT | control=111; 1) 107; 2) 50; 3) 53 | 25% white; 75% minority; 33% currently married, ave. 11 years of education; ave. 21 yrs of age; Greensboro, NC. | Women in their third trimester who received care at the public prenatal clinic and delivered at the community hospital. | Criteria include: uncomplicated pregnancy at the third trimester, no previous delivery of nonviable infant; not expecting twins; intended to say in the area for one year or more; did not have a family member in the study. | 3rd trimester of pregnancy through 12 months | Control group received usual care. Intervention 1: early and extended hospital contact and home visits; 2: early and extended hospital contact only; 3: home visits only. | Data was collected by interview during the last trimester of pregnancy, and by interview and observation in the home at 4 months and 12 months post delivery. Hospital and health agency records were also reviewed. Measures: 92 item Attachment Inventory, Peabody Picture Vocabulary Test. | No differences in reports of child abuse and neglect, the number of hospitalizations, or the number of emergency room visits. | FAIR
Cerny, 2001^105^ | Cohort | 142 | Pregnant women during the first trimester at risk for child abuse or neglect; mean age 23 yrs; 66.4% enlisted rank; 21% African American; 73% married; many qualified for federal assistance; Tripler Army Medical Center. | Mothers receiving care at a military medical center. | One or more of the following risk factors: unrealistic expectations of children, lack of support, high stress, marital problems, single parenthood, poor parenting imprint, negative attitude toward pregnancy, social isolation, inappropriate coping skills, history of spouse abuse, history of emotional, physical or sexual abuse. | Prenatal through 1 yr | Community health nurse visited the home approximately 2 times per month until 1 yr post-partum. Education provided for healthy pregnancy, bonding, breastfeeding, infant care, nurturing, discipline, infant massage, domestic violence, etc. | Pre and Post CAP within 3 weeks of program commencement, at 12 months post-partum; also demographic data. | Mothers were placed in either high or low child abuse potential groups based on CAP scores. High and low potential mothers had statistically significant changes in CAP scores pre and post test (P<0.001). Mothers in the high risk group had significantly more reports of past or present psychological problems, relationship problems, or spouse abuse (P<0.05). | FAIR-POOR
Katzev, 1999^88^ | Cohort | High risk group = 4,903; | First-birth pregnant women receiving care in a healthcare or other service provider office; various counties in Oregon. | Providers identify high risk patients, then screen for potential family stress. | First-birth mothers identified by provider (by direct contact or health records) to be at high risk for abuse or neglect using the 15 item Hawaii Risk Indicator Scale. If high risk, then given a Kempe Family Stress Inventory and referred to the intensive program. | Prenatal to 3 years | High risk patients received weekly home visits, child development information, parenting support, referrals, access to parent support groups, and community resources. Low risk patients received usual service (welcome home visit). | Child's development, literacy, healthcare utilization, immunization, family's basic resources, coping, risk processes, child-parent interactions, and child maltreatment. | No significance levels given. Child abuse incidence rate was 12 per 1,000 children in the treatment group, 17 per 1,000 in the control group; 17% decrease in family violence in the treatment group after 18 months of the intervention. Treatment families had 78% positive parent-child interactions at 6 months, 45% at the start of the program. | FAIR-POOR
| | Low risk group = 2,018
Brayden, 1993^89^ | RCT | High risk intervention =160; | Pregnant women receiving prenatal care at University Hospital, Philadelphia PA. | Eligibility screening was done at a prenatal care hospital clinic. | High risk was determined by criteria (frequent moves, previous removal of children by CPS, abusive behavior) and high scores on the Life Stress Scale and Nurture Scale. | Prenatal to 2 yrs of age | High risk intervention included comprehensive services; control had usual care. Comprehensive services included care by a multidisciplinary team for prenatal, postnatal, and pediatric care until children were 2 yrs of age. | Maternal History Interview (MHI), risk based on criteria and scores on scales. Outcomes determined by public agency document reports of physical abuse, neglect, sexual assault, or mother-child separation through 36 months post-delivery. | Scores on the MHI predicted child abuse, but not neglect or sexual abuse. Child abuse reports for high risk control mothers were 6.6%, 2.3% for low risk controls (RR 3.02, CI 1.02–8.90). No prevention effect was demonstrated for physical abuse. When compared to high risk controls, the high risk intervention group had higher physical abuse and neglect reports, with neglect reaching significance. | POOR
| | High risk control=154;
| | Low risk=768;
| | 295 randomly selected for follow-up
Dawson, 1989^104^ | Quasi-experimental | Control=80; 1) 42; 2) 50 | Median family income $5,500; 74% white, 25% Mexican American, 1% African American; 66% expecting first child, 34% their second; median education 11th grade; 71% lived with the baby's father, 19% with parents, 10% other; Denver, Colorado. | Women were recruited from 3 clinics in a maternity and infant care project of a local health department between 1977 and 1978; 92% of those approached agreed to participate. | Mother expecting her first or second child, 20–26 weeks pregnant, at least 16 yrs of age, English speaking and not planning to move. No other screening was done. | 30th week of pregnancy through 14 months | Control group received usual care. Intervention 1 received usual care plus weekly home visits. Intervention 2 received usual care, home visits, plus invitations to parent groups that met twice a month. | Pregnancy outcomes and medical information were obtained from medical records; family stress index and other household ratings were obtained by the social worker. Clinic records and state records were used to determine actual or potential abuse and/or neglect. | There were more reports of suspected child abuse or neglect in the home visited group (p=0.04); in 3 of the 5 reported cases, it was the home visitors' information that led to the report. | POOR
Flynn, 1999^106^ | Cohort | 137 | Pregnant women receiving prenatal care; 71% African American, 27% Hispanic; mean age 16.9; Newark, NJ. | Pregnant mothers referred by local medical clinics or healthcare providers (some self-referred). | Pregnant with first child or 6 weeks postpartum and considered at risk for child maltreatment. Also, participants were aged 18 or younger, Medicaid eligible, city residents, and not currently clients of Division of Youth and Family Services. | Prenatal through 3 years | Based on the Healthy Families America model of intensive home visiting. 4 levels of mentor intervention were given. Level I=intense support with weekly and monthly visits. When the family became ‘crisis free for 30 days’, a less intense level of home visiting was implemented (Levels II – IV). | A nursing assessment was done on each adolescent prior to the study. The CAP was administered and a home assessment completed following the birth of the baby and 8 to 12 months post-birth. Incidence of child abuse and neglect were confirmed by the local division of Youth and Family Services. | Only 19 of the 137 completed the CAP at times 1 and 2. Preliminary results indicate a decrease in child abuse potential at time 2 (p<0.009). | POOR
Gray, 1979^103^ | RCT | High risk intervention=50; | Women pregnant with their first or second child. Denver, Colorado. | From 1971-1973, pregnant women attending the Colorado General Hospital. | Parents considered at high risk for “abnormal parenting practices” by data gathered at labor & delivery, prenatal interview, or video were recruited. Controls were mothers assessed as low risk and delivered at the hospital during the same period. | Prenatal to age 17–35 mo | High risk mothers were randomized to intervention and non-intervention groups, a third group was considered a low-risk control group. Intervention consisted of specialized pediatric care (pediatrician met with the family at delivery and for bimonthly and medical visits, and made periodic personal phone calls) and weekly home visits by nurses. | Risk for abuse was determined using prenatal and postpartum data. Outcomes were assessed when infant was 17 to 35 months old. Families were interviewed and records reviewed (observations of mother-child interactions, reports of verified abuse and neglect, hospital and medical records, and the Denver Developmental Screening Test). | Compared to the high risk non-intervention group, the high risk intervention group had more reports to the Central Child Abuse Registry (6 cases for intervention group, 2 for non-intervention group, p<0.08), but fewer cases of inpatient treatment for injury (no cases for intervention group, 5 cases for non-intervention group, p<0.01). Several other measures were not different between groups. | POOR
| | high risk non-intervention=50;
| | low-risk control=50

Table 3 Summary of Child Abuse and Neglect Intervention Studies

Author, Year | Type of study | Population/age of child when intervention ended | Assessed for risk | Significant decrease in abuse measures | Other significant effects* | Quality Rating
Olds, 1986, 1994, 1995, 1997^92^–^95^ | RCT | Pregnant women/ 24 mos | X † | | | GOOD
Follow-up: 2 yrs | | | | X (p=0.07) | X
3 yrs | | | | 0 | X
4 yrs | | | | 0 | X
15 yrs | | | | X | X
Eckenrode, 2000^96^ | RCT
15 yrs | | | | X | X
Barth, 1991^97^ | RCT | Pregnant women/ 6 mos | X† | 0 | X | FAIR
Black, 1994^99^ | RCT | Drug-using pregnant minority women/ 18 mos | X (drug use) | NA | X | FAIR
Brooten, 1986^102^ | RCT | Low birth weight infants/ 18 mos | X (low birth wt) | 0 | X | FAIR
Kitzman, 1997^101^ | RCT | Poor minority women/ 24 mos | X† | NA | X | FAIR
Marcenko, 1994^98^ | RCT | Pregnant minority women/ 6 mos | X† | 0 | X | FAIR
Seigel, 1980^100^ | RCT | Pregnant women/ 12 mos | No | 0 | 0 | FAIR
Cerny, 2001^105^ | Cohort | Pregnant military women/ 12 mos | X† | 0 | X | FAIR-POOR
Katsev, 1999^88^ | Cohort | Pregnant women/ 36 mos | X (HRIS/KFSI) | X | X | FAIR-POOR
Brayden, 1993^89^ | RCT | Pregnant women/ 24 mos | X† | X | NA | POOR
Dawson, 1989^104^ | Quasi-experimental | Poor, pregnant women/ 24 mos | No | Increased reports | NA | POOR
Flynn, 1999^106^ | Cohort | Poor, minority pregnant women/ 36 mos | X‡ | 0 | X | POOR
Gray, 1979^103^ | RCT | Pregnant women/ 36 mos | X‡ | Increased reports | X | POOR

X=significant relationship; 0=studied but not significant; NA=not studied

* Other outcomes include injury, poisoning, hospitalizations, child development level, and others.

† Assessment based on study criteria.

‡ Assessment based on clinical judgment.

HRIS=Hawaii Risk Indicator Scale

KFI=Kempe Family Stress Inventory

Figure 3. Literature Search Results

Randomized controlled trials meeting criteria for good quality. A trial of 400 low income, pregnant women in a semi-rural county in New York State provided 3 levels of support services during and after pregnancy and assessed outcomes related to child abuse and neglect.^92^ Women were actively recruited to the study through a variety of ways, including public health clinics and obstetric practices, if they had no other previous live births and were either younger than 19, single parents, or had low socioeconomic status, although women who requested to be in the study were also included. They were randomized to 1 of 4 groups including: no intervention, intervention with transportation services to the medical clinic during pregnancy, intervention with transportation services and nurse home visits during pregnancy (every 2 weeks for approximately 9 visits), and intervention with transportation services and nurse home visits continuing through the child's second birthday. Nurse visits included parent education, support systems for the mother, and engagement of family members with other health and social services.

All infant participants received a sensory, developmental, and home environment evaluation at 1 and 2 years of age using Bayley, Cattell, and Home Observation for Measurement of the Environment (HOME) Scales. In addition, records from the department of social services (Child Protective Services), emergency room visits, and other medical visits were reviewed for the presence of abuse and/or neglect. If there were suspected problems in the no intervention group at the 1 or 2-year evaluation, subjects were referred to appropriate services. Data were also collected at ages 3,^93^ 4,^94^ and 15.^95, ^ ^96^ At the 15-year follow-up, outcome data included a life history calendar, self-report of criminal activity, parent-child conflict inventory, and domestic violence assessment.

Results at 2 years showed that high-risk women who had prolonged nurse visits were less likely to commit acts of child abuse and neglect compared to high-risk women without visits (p=0.07).^92^ At 3 and 4 years follow-up, there were no differences between groups for child abuse and neglect outcomes.^93, ^ ^94^ At the 15-year follow-up, however, differences were reported. Children in the nurse-visited group were less likely to be involved in reports of child maltreatment of any kind (p=0.004).^96^ Mothers in the nurse-visited group were less likely to be perpetrators of child abuse and neglect than mothers without nurse visits 15 years after the intervention (p=0.01).^95^

Other related outcomes included fewer injuries or toxic ingestions at ages 2, 3, and 4,^92^–^94^ and fewer visits to the emergency department at ages 3 and 4^93, ^ ^94^ for the nurse-visited group. Also, at the 2-year assessment, nurse-visited toddlers showed a higher developmental quotient than non-visited toddlers.^92^ When compared to non-visited mothers, mothers in the nurse-visited group showed less impairment by alcohol and other drug use, less convictions, and less jail time at the 15-year follow-up.^95^ However, this finding was statistically significant only for the subgroup of unmarried women with low socioeconomic status.

Randomized controlled trials meeting criteria for fair quality. Six fair-quality trials evaluated home visitation programs linked to prenatal clinics or hospital care.^97^–^102^ All but one study^100^ used inclusion criteria to assess risk for child abuse and neglect, although no study used standardized or validated instruments. Studies generally considered positive responses to criteria such as social or demographic risk factors (unmarried, low level of education, unemployed),^97, ^ ^101^ drug use during pregnancy,^99^ low birth weight,^102^ or a history of other risk factors (HIV infection, homelessness, substance use),^98^ among others. Follow-up ranged from 2 to 24 months post delivery, and abuse outcomes were determined by medical record review, face-to-face interviews, home observation, questionnaires on child abuse potential, and county social service records. Evaluations of the home included assessment of the safety and developmental appropriateness of the home and play environment.

None of these studies described significantly fewer reports of abuse and neglect in intervention groups compared to control groups. Five of the studies reported other significant intervention effects related to abuse and neglect such as medical care utilization, parent-child interactions, punishment, stressful life events, parental mental illness, and drug use.^97^–^99, ^ ^101, ^ ^102^

A trial in Memphis randomized 1,139 pregnant women seen in a public obstetric clinic to 4 different intervention groups including a home nurse-visit group.^101^ This study had a similar design as the New York State trial,^92^ but differed in implementation of the intervention and measurement of outcomes. Also, study groups had different income levels at baseline. Outcome measures included mothers' perceptions of child abuse and neglect, punishment, and child rearing, medical visits, and life events, but no verified reports of abuse and neglect. By the 24th month, nurse-visited women held fewer beliefs about child-rearing associated with child abuse and neglect such as lack of empathy, belief in physical punishment, and unrealistic expectations of an infant (p=0.003). Nurse-visited children had fewer health care encounters related to injuries or ingestions in the first 2 years, compared to comparison groups (p=0.05).

A prenatal assessment indicated that 43 drug-using minority women had Child Abuse Potential (CAP) scores significantly above the norm (p<0.01).^99^ At 18 months follow-up, an intervention group that had received biweekly nurse home visits reported total abuse scores on the CAP to be within the norm, while the control group continued to show total scores above the norm (p<0.01). Women in the treatment group were more emotionally responsive to their children (p=0.03), had a more stimulating home environment (p=0.053), reported being drug free (p=0.002) and were compliant with primary care (p=0.016) compared to the women without home visits.

In a trial conducted in California, 191 pregnant women were referred to a specialized home visitation program after being identified as high risk and were followed for 2 months postpartum.^97^ Before the program, the intervention group had more reports of child abuse than the control group. Following the intervention, the control group had a greater increase in unsubstantiated reports (p<0.05). No differences were seen for substantiated reports, well-being, prenatal care, birth outcomes, baby temperament, child welfare, or court-ordered in-home or out-of-home services.

225 pregnant minority women in Philadelphia participated in a study of home visitation from prenatal to 12 months postpartum.^98^ There were no significant differences between groups on the HOME inventory. Treatment women showed a decrease in overall psychological distress (p<0.002), had more help with household tasks and attaining household items (p<0.001), higher total social support (p<0.005), and more support from grandparents (p=0.04) and friends (p<0.004).

A trial of nurse home visitation for low birth weight babies included 79 postpartum women at the University of Pennsylvania Hospital.^102^ Low birth weight infants in the intervention group were discharged 11 days earlier (p<0.05) than the control group, and were on average 2 weeks younger. At 18 months follow-up, there were no differences between groups for reports of child abuse or foster care placement, measures of re-hospitalizations, numbers of acute care visits, or incidence of failure to thrive.

Summary of child abuse and neglect interventions.

- A good-quality randomized controlled trial of nurse home visits during pregnancy and for 2 years after delivery indicated improved child abuse and neglect outcomes, as well as improved related outcomes such as criminal activity, perpetrator status, drug use, etc. These effects persisted for 15 years after the intervention. Most of the positive results of this intervention were concentrated among mothers who were unmarried and from low-income households.
- Other trials do not indicate improved child abuse and neglect outcomes, but report improvements in related outcomes.
- All studies of interventions focused on newborns and infants.
- All studies of interventions included women considered at high risk for abuse because of sociodemographic characteristics and/or inclusion criteria based on additional risk factors.

## Intimate Partner Violence against Women

### Screening

Of 806 abstracts identified by searches of MEDLINE, PsycINFO, and Health & Psychosocial Instruments (Appendix 1); 14 met inclusion criteria. These include 6 studies that compared one instrument to another^26, ^ ^107^–^111^, 3 that compared an instrument to a directed interview^112^–^114^, 2 that measured inter-rater reliability and/or internal consistency^115, ^ ^116^, and 3 that compared methods of administration^76, ^ ^117, ^ ^118^. None evaluated the performance of a screening instrument or procedure using verified abuse outcomes. Instruments are described in Appendix 3.

Six studies compared brief screening instruments to previously validated instruments and were rated good or fair in quality (Table 4).^26, ^ ^107^–^110^ Results indicated that the brief instruments were generally correlated to longer instruments and in some cases performed better.

Table 4 Studies of Intimate Partner Violence Screening Instruments

Author Year | N | Population/Setting | Instruments | Results | Quality Rating/Limitations
Comparison of Screening Instruments
Coker, 2001^107^ | 1152 | Ages 18–65 (mean 38.1) | 1) Women's Experience with Battering Scale (WEB), 10 items; 2) Index of Spouse Abuse-Physical Scale (ISA-P), 15 items | Higher detection rate with WEB scale (16%) than ISA-P (10%) | FAIR;; 1) Questions asked by graduate students (not health care professionals); 2) Uses modified version of reference standard; 3) Administered verbally, although designed as written questionnaires
| | 62% African-American | All subjects screened with both instruments
| | 38% White
| | All insured by Medicaid or managed care
| | 2 university-affiliated family practice clinics
Brown, 2000^108^ | 307 | Mean age: 46.2 (range 18–86) | 1) Woman Abuse Screening Tool (WAST), 8 items; 2) Abuse Risk Inventory (ARI), self-report, 25 items | 1) WAST and ARI results were correlated (r=0.69, p=0.01); 2) WAST showed good internal consistency (Cronbach's alpha=0.75) | FAIR; An additional question was added to the original 7-item WAST
| | 97.6% White
| | 44.7% with postsecondary education
| | 58.9% employed
| | 58.7% with annual household income >$30,000
| | 20 family practice offices
Sherin, 1998^109^ | 259 | Demographics not given | 1) HITS, written, 4 items; 2) Conflict Tactics Scales (CTS), verbal, 19 items | 1) HITS internal consistency (Cronbach's alpha=0.80); 2) Results of HITS and CTS were correlated (r=0.85) | GOOD
| | Family practice office, urban/suburban population
Feldhaus, 1997^110^ | 322 | Mean age: 36 | 1) Partner Violence Screen (PVS), verbal, 3 items; 2) Index of Spouse Abuse (ISA). written, 30 items; 3) Conflict Tactics Scales (CTS), verbal, 19 items | PVS had a higher sensitivity & specificity when compared to the ISA (64.5% & 80.3%) or CTS (71.4% & 84.4%) | GOOD: Screening done by research assistant (not health professional)
| | 45% White
| | 19% African-American
| | 30% Hispanic
| | 49% employed
| | 69% income <$15,000
| | 67% HS or > education
| | 2 urban, hospital-based emergency departments
Comparison of Screening Instruments
McFarlane, 1992^26^ | 691 | 31% teenagers; 39% African-American, 34% Hispanic, 27% White pregnant women in public prenatal clinics | Abuse Assessment Screen (AAS), 3 items, compared with Index of Spouse Abuse (ISA), Conflict Tactics Scales (CTS), and Danger Assessment Screen (DAS) | Women identified as abused on the AAS also scored significantly higher on the ISA, CTS, and DAS | GOOD
Ernst, 2002^111^ | 488 | Median age 36, 47% white, 26% African-American, 11% Hispanic Large metropolitan emergency center | Abuse Assessment Screen (AAS), Ongoing Abuse Screen (OAS), single question “Are you presently a victim of IPV?” | The OAS had a sensitivity of 30%, specificity of 100%, and a positive predictive value of 100% | GOOD
Comparison of Screening Instrument to Interview
Morrison, 2000^112^ | 302 | Mean age and range not specified 1000 charts reviewed | 1) Emergency Dept Domestic Violence Screening Questions, 5 items; 2) Standard interview, chart review | 1) Retrospective review of 1000 charts identified 4 patients (0.4%) as past or present victims of domestic violence; 2) Higher detection rate with questionnaire (3.6% acute, 6.6% probable, 4% past abuse) | POOR: Inappropriate reference standard (interview not defined)
| | Emergency Department, tertiary hospital
Canterino, 1999^113^ | 224 | Mean age: 24.4 | 1) Domestic Abuse Assessment Questionnaire, self-report, 5 items; 2) Directed interview | Self-report questionnaire yielded higher detection rate (85% vs. 59%, p=0.03) | POOR: Inappropriate reference standard (interview not defined)
| | 53.8% African-American
| | 30.1% White
| | 11.4% Hispanic
| | 36% employed
| | Prenatal clinic, community-based tertiary care center
Norton, 1995^114^ | 143 | Median age: 23 | 1) Abuse Assessment Screen (AAS), 5 items; 2) Standard interview, chart review | Higher detection of violence using AAS (41%) compared with interview (14%) | POOR: Inappropriate reference standard (interview not defined), narrow spectrum (pregnant women)
| | 50% White
| | 63% single
| | 42% uninsured
| | Prenatal visit, interviewed by social services
Internal Consistency of Screening Instrument
Pan, 1997^115^ | 90 | Mean age: 37.8 | Partner Abuse Interview, 11 items, (modified CTS) | Internally consistent (Cronbach's alpha=0.82) | FAIR:; 1) Small sample size; 2) Inappropriate reference standard (not compared to another method)
| | 13.7 years average education
| | $32,000 mean family income
| | 82% White
| | 6% African-American
| | 7% Hispanic
| | 3% Asian
| | Suburban family practice clinic, tertiary university hospital
Smith, 1995^116^ | 389 | 85% White | WEB Scale, 10 items | High internal consistency (Cronbach's alpha for full sample=0.99; battered=0.93; non-battered=0.86) | FAIR: Inappropriate reference standard (not compared to another method)
| | 61% HS or >education
| | 68% employed
| | Various primary care clinics and community groups
Comparison of Methods of Administration of Screening Instrument
Glass, 2001^76^ | 4641 | Women aged 18 and older who came to emergency department at 11 community hospitals | Abuse Assessment Screen (AAS) as part of intake survey; patients chose whether to self administer or have it read by a nurse interviewer | Prevalence of lifetime and past year abuse was higher with self-administered questions | FAIR: Patients self-selected method
Furbee, 1998^117^ | 175 | Mean age 34 | 1) Face-to-face interview; 2) Tape-recorded questionnaire with written answer sheet 83 participants listened to tape 92 interviewed by physician | Comparable results (16% prevalence of abuse detected with face-to-face interview compared with 15% detected with taped interview) | FAIR: Narrow spectrum of patients
| | Emergency deparment, rural, university-affiliated
McFarlane, 1991^118^ | 777 | 59% in age range 20–29 | 1) Self-Report, 4 items; 2) Interview, 4 items 477 given self-report 300 given interview | Higher prevalence of abuse was detected by nurse interview (29.3%) than by self-report (7.3%) | FAIR: Narrow spectrum of patients
| | 47% Black
| | 34% White
| | 17% Hispanic
| | One Planned Parenthood clinic

The HITS instrument includes 4 questions about being Hurt, Insulted, Threatened, or Screamed at.^109^ When administered to 259 women in a family practice office, it demonstrated fair internal consistency (Cronbach's alpha=0.80), and its results correlated with the previously validated 19-item Conflict Tactics Scales (CTS) (r=0.85). In urban emergency department settings, the Partner Violence Screen (PVS), consisting of 3 questions, had higher sensitivity and specificity when compared to either the 30-item Index of Spouse Abuse (ISA) (64.5% & 80.3%) or the Conflict Tactics Scales (71.4% & 84.4%).^110^ However, the Conflict Tactics Scales may not have undergone sufficient testing of its validity to qualify as a gold standard in these studies.

A study of 1,152 predominantly African-American women presenting for care at university-affiliated family practice clinics found that the 10-item Women's Experience with Battering Scale (WEB) had a higher detection rate (16%) than the 15-item Index of Spouse Abuse-Physical Scale (ISA-P) (10%).^107^ Another trial with predominantly white women in family practice clinics found that the 8-item Woman Abuse Screening Tool (WAST) was correlated to the 25-item Abuse Risk Inventory (ARI) (r=0.69).^108^ A study of pregnant women in public prenatal clinics tested the 3-item Abuse Assessment Screen (AAS) against the Index of Spouse Abuse (ISA).^26^ Women identified as abused on the AAS also scored significantly higher on the ISA than women who had not been abused.

The previously validated Abuse Assessment Screen (AAS) was modified to detect present abuse, rather than abuse within the previous 12 months, for use in the emergency department setting and re-named the Ongoing Abuse Screen (OAS).^111^ Women presenting to an emergency department were screened with both instruments as well as with a single. The Abuse Assessment Screen yielded positive results in 59% of women screened, and the Ongoing Abuse Screen yielded positive results in 16%. The single question, “Are you presently a victim of intimate partner violence?” yielded positive results in 3% of women.

Three studies comparing a screening instrument to an interview were rated as poor quality.^112^–^114^ The major limitation of these studies is that no protocol for the directed interview was identified. These studies reported higher detection rates with questionnaires than with interviews.

Two fair quality studies measured the internal consistency of screening instruments^115, ^ ^116^. The Partner Abuse Interview, an 11-item questionnaire modified from the Conflict Tactics Scales, showed fair internal consistency (Cronbach's alpha=0.82) when tested in 90 women at a suburban family practice clinic and university hospital.^115^ The Women's Experience with Battering (WEB) Scale, a 10-item questionnaire tested in primary care clinics and community groups, showed good internal consistency (Cronbach's alpha 0.99).^116^

Three fair quality studies compared methods of administration of screening instruments.^76, ^ ^117, ^ ^118^ A study of 4,641 women presenting to 11 community emergency departments found that the prevalence of past year and lifetime violence was significantly higher when a questionnaire containing items from the Abuse Assessment Screen (AAS) was self-administered than when it was administered by a nurse.^76^ In another study conducted in an emergency department, reports of abuse were similar when a questionnaire was given as part of a face-to-face-interview (16%) and when a taped-recorded questionnaire with a written self-reported answer sheet was provided (15%).^117^ In a study at a Planned Parenthood clinic using the AAS, rates were higher with a nurse-conducted interview (29%) than by self-report (7%).^118^

Summary of intimate partner violence screening. Several instruments have been developed for intimate partner violence screening; some have demonstrated fair to good internal consistency and some have been validated with longer instruments. None, however, have been evaluated against measurable intimate partner violence outcomes. The optimal methods of administration have not been determined, but may vary by setting and patient population.

### Interventions

Of 667 abstracts identified by searches of MEDLINE, CINAHL, and PsycINFO (Appendix 1) only 2 met inclusion criteria (Table 5). These fair quality studies evaluated interventions for abused pregnant women and reported lower levels of violence after delivery even when a minimal or “brief” intervention was performed;, neither study had a non-intervention control group.^119, ^ ^120^

Table 5 Studies of Intimate Partner Violence Interventions

Author, Year | Design | N | Population/Setting | Duration | Intervention | Assessment | Results | Quality Rating
McFarlane, 2000^119^ | Randomized trial comparing 3 interventions | 329 | Pregnant Hispanic women at prenatal clinics in SW US | Monitored at 2-,6-,12-,& 18-months post-delivery | 1) “Brief” (wallet-sized card with resources), 2) “Counseling” (unlimited access to counselor in clinic), 3) “Outreach” (counseling plus ‘mentor mother’ in community) | All women were screened using the Abuse Assessment Screen (AAS); those with positive responses were randomized to intervention groups and outcomes were determined by the Severity of Violence Against Women Scale (SVAWS) at each follow-up visit. | Abuse decreased significantly in all groups; there were no statistically significant differences between the 3 groups at 6, 12, & 18 months; at 2 months scores were significantly lower for the outreach group compared to the counseling group but not compared to brief group. | FAIR: Narrow patient population, outcomes by self-report
Parker, 1999^120^ | Non-randomized trial comparing 2 interventions | 199 | Pregnant women at prenatal clinics in Texas and Virginia; 35% Black, 33% Hispanic, 32% White | Monitored at 6 & 12 months post-delivery | 1) 3 counseling sessions, 2) wallet-sized card with resources (intervention vs. minimal intervention) | Women were screened with AAS; those with positive responses were eligible for interventions; outcomes were determined by SVAWS and Index of Spouse Abuse (ISA) at each follow-up visit. | Less violence occurred in the intervention group at 6 and 12 months, (SVAWS [p=0.052], ISA [p=0.007]). | FAIR: Non-random assignment, outcomes by self-report, poor attendance at support groups

In one study, 329 pregnant Hispanic women in a prenatal clinic who tested positive for abuse on a screening questionnaire (Abuse Assessment Screen [AAS]) were randomized into 1 of 3 groups: “brief” (given wallet-sized card listing community resources); “counseling” (unlimited access to counselor in clinic); or “outreach” (counseling plus “mentor mother” in the community).^119^ At a 2-month follow-up, violence scores measured using the Severity of Violence Against Women Scale (SVAWS) were significantly lower in the outreach group compared to the counseling group, but not compared to the brief group. However, at the 6-, 12-, and 18-month follow-ups, violence scores were decreased in all groups without statistically significant differences between groups.

In another study of pregnant women in prenatal clinics with positive responses on the AAS, 132 were given 3 counseling sessions, while 67 were offered wallet-sized cards listing community resources.^120^ At 6 and 12 months post delivery, less violence occurred in the intervention group as measured by the Index of Spouse Abuse (ISA) (p=0.007) and SVAWS (p=0.052).

Summary of intimate partner violence interventions. Few intervention studies have been conducted and these focused on pregnant women. Outcomes were based on scores on questionnaires and suggest benefit, however study limitations restrict interpretation.

## Elder Abuse and Neglect

### Screening

Of 1,045 abstracts identified by searches of MEDLINE, PsycINFO, Health & Psychosocial Instruments, and AARP Ageline (Appendix 1), 3 studies of elder abuse screening instruments met modified inclusion criteria (Table 6; Appendix 3). None were developed or tested in traditional clinical settings. However, because the care of elderly adults occurs largely outside these settings, they were included in this review if they appeared that they could be adapted to a clinical setting.

Table 6 Studies of Elder Abuse and Neglect Screening Instruments

Author, Year | N | Population/Setting | Instruments | Results | Quality Rating/Limitations
Caregiver Screen
Reis, 1995^121^ | 139 | 3 groups of caregivers: 44 abusive and 45 non-abusive from social service agency, 50 non-abusive from community. | Caregiver Abuse Screen (CASE), 8 items (yes/no) | 1) Scores distinguished abusers from non-abusers (alpha=0.71); other characteristics were similar (SES, age, etc.); 2) CASE scores correlated with Indicator of Abuse (IOA) (r=0.41, p<0.001). 3) CASE scores correlated with Sengstock-Hwalek Brief Abuse Screen (r=0.26, p<0.025) | FAIR: Small sample size, administered as part of a social services project, not in clinical setting
Elder Screen
Neale, 1991^122^ | 259 | 3 groups of elders: 170 victims of abuse, 42 referred to Adult Protective Services (APS) and found not to be abused, 47 from a family practice clinic. | Hwalek-Sengstock Elder Abuse Screening Test (HSEAST), 15 items | Scores distinguished abused from not abused (p<0.001; Cronbach's alpha=0.29); correctly classified 67–74% of cases; 6 items were strongly related to abuse | FAIR: Small sample size
Moody, 2000^123^ | 100 | Convenience sample of white and minority elderly (>60 years) living in public housing in Florida. | 1) Hwalek-Sengstock Elder Abuse Screening Test (HSEAST), 15 items; 2) Indicators of Abuse (IOA) Screen, 29 items | Scores for abused and nonabused were significantly different (p<0.049); correctly classified 71% of cases. Discriminates abuse cases 84.4% of the time, and nonabuse cases 99.2% of the time. | FAIR: Small sample size, Intended for social service practioners

A screening instrument for caregivers was tested in 3 groups: abusive and non-abusive caregivers from a social service agency, and non-abusive caregivers from the community.^121^ The Caregiver Abuse Screen (CASE) is based on yes or no responses to 8 items. Scores on CASE distinguished abusers from non-abusers (Cronbach's alpha=0.71), and correlated with previously validated instruments: Indicator of Abuse (IOA) (r=0.41, p<0.001), and Sengstock-Hwalek Brief Abuse Screen (HSEAST) (r=0.26, p<0.025).

Two studies described screening groups of elderly adults. One study used 3 groups: victims of abuse, individuals referred to Adult Protective Services as potential victims and found not to be, and non-abused elderly adults from a family practice clinic.^122^ The 15 item, HSEAST was administered to all groups and correctly classified 67–74% of cases (p<0.001). The HSEAST was also evaluated in a study of elderly adults living in public housing in Florida^123^. Abuse status (past abuse or none) was reported by participants and verified by a social worker who reviewed their records at the housing authority. Scores for the abused and nonabused persons were significantly different (mean total score, 4.01 vs 3.01; P=0.049). This study also indicated that a 9-item model performed as well as the longer 15-item version, correctly identifying 71.4% of abused persons with 17% false-positive and 12% false-negative rates.

Summary of elder abuse and neglect screening. Only a few screening instruments have been developed to identify potential elderly victims of abuse or their caretakers. These instruments performed fairly well when administered in the study, but have not been tested in the primary care setting.

### Interventions

Of 1,084 abstracts identified by searches of MEDLINE, CINAHL, PsycINFO, or AARP Ageline (Appendix 1), 72 articles were retrieved for further review; however, none provided data about effective interventions. Some papers provided descriptions of individual elder abuse programs, but did not include comparison groups or health outcome measures.

## Adverse Effects of Screening and Interventions for Children, Women and Elderly Adults

No studies were identified that provide data about adverse effects of screening or interventions for family and intimate partner violence for children, women, or elderly adults. No screening instrument demonstrated 100% sensitivity and specificity. False-negative tests may discourage clinicians from seeking further history and inhibit identification of those who are truly at risk. False-positive tests results, most common in low-risk populations, can lead to inappropriate labeling and punitive attitudes. Additional possible adverse effects include psychological distress and escalation of abuse and family tension, loss of personal residence and financial resources, erosion of an established family structure, loss of autonomy for the victim and, lost time from work. Children could lose contact with established support systems including neighbors, siblings, school contacts, and peer groups. Women who have an abuser can become the target of retaliation, which can lead to homicide^62^.

There has been concern that patients may feel uncomfortable or threatened if asked questions about family and intimate partner violence. Most women in a study of screening in antenatal clinics believed it was a good idea (98%) and felt “ok” during the process (96%) when asked at a subsequent visit.^124^ In another study, only 3% of women found screening with the Abuse Assessment Screen unacceptable when asked at 3 different points during and after pregnancy.^125^ Although most women presenting with their children to a pediatric emergency department believed screening for intimate partner violence was appropriate, many indicated that their willingness to disclose might be affected by fear of being reported to child protective services.^126^ This concern was confirmed by clinicians in the study indicating that they would feel obligated to report a child to protective services if violence was present in the home.

A telephone survey of abused and non-abused women in 11 U.S. cities indicated that abused women were less likely to support mandatory reporting compared to non-abused women (59% vs 73%, p<0.01). Reasons included that victims would be less likely to disclose abuse, would resent someone else having control of the situation, and reporting would increase the risk of perpetrator retaliation.^127^ These points were also made in another survey of women in a health maintenance organization. ^128^