# Methods

## Literature Search Strategy

In conjunction with a medical librarian, we conducted searches using MEDLINE (1966 to December 2002), PsycINFO (1984 to December 2002), CINAHL (1982 to December 2002), Health & Psychosocial Instruments (1985 to December 2002) (women and elderly adults only), ERIC (1989 to December 2002) (children only), AARP Ageline (1978 to December 2002) (elderly adults only), and the Cochrane Controlled Trials Register (Appendix 1). Additional articles were obtained by reviewing reference lists of pertinent studies, reviews, and editorials, and by consulting experts. References listed in a recent review of early childhood home visitation for the prevention of violence for the U.S. Task Force on Community Prevention Service,^80^ the Prevention of Child Maltreatment Update from the Canadian Task Force on Preventive Health Care,^81^ Violence in Families: Assessing Prevention and Treatment Programs^82^, a systematic review of screening women in health care settings for domestic violence^72^ and other systematic reviews were specifically considered.

## Inclusion/Exclusion Criteria

Inclusion and exclusion criteria were developed by the investigators in collaboration with the USPSTF for each population. Studies included in this review had English-language abstracts, were applicable to U.S. clinical practice, described abuse and violence against women, children, or elderly adults, were conducted in or linked to primary care (family practice, pediatrics, and general internal medicine), obstetrics/gynecology, or emergency department settings, and included a physician or other health provider in the process of assessment or intervention. We excluded studies about patients presenting with trauma.

Studies about assessment were included if they evaluated the performance of verbal or written questionnaires or other assessment procedures such as physical examinations that were brief and applicable to the primary care setting. Included studies clearly described the study sample, the screening instrument or procedure, the abuse or neglect outcome, and the collection of data. Outcomes included indicators of physical abuse, neglect, emotional abuse, and/or sexual abuse and related health outcomes if reported such as depression.

Studies about interventions were included if they measured the effectiveness of an intervention in reducing harm from family and intimate partner violence compared to comparison groups. Results from properly conducted randomized controlled trials were emphasized. We excluded studies that tested effectiveness of interventions to educate health care professionals about family violence or increase screening rates in institutions. We also excluded studies about mandatory reporting laws, descriptions of programs, the accuracy of physician diagnosis and reporting of abuse, and physician factors related to reporting.

## Data Extraction and Synthesis

From each included study, we abstracted the study design, number of participants, setting, length and type of interventions, length of follow-up, outcomes, methods of outcome measurement, and study duration, among others. Two reviewers independently rated each study's quality using criteria specific to different study designs developed by the USPSTF, and categorized them as good, fair, or poor (Appendix 2).^83^ When reviewers disagreed, a final score was reached through consensus.