# Appendix 3: Screening Instruments

## Child Abuse and Neglect

### Hawaii Risk Indicators Screening Tool

Based on medical record or interview; score true, false, unknown

1 Unmarried
2 Partner unemployed
3 Inadequate income
4 Unstable housing
5 No phone
6 Education under 12 years
7 Inadequate emergency contacts
8 History of substance use
9 Inadequate prenatal care
10 History of abortions
11 History of psychiatric care
12 Abortion unsuccessfully sought or attempted
13 Adoption sought or attempted
14 Marital or family problems
15 History of depression

Positive screen: true score on either item number 1, 9, or 12; two or more true scores; seven or more unknowns

Duggan A, Windham A, McFarlane E, Fuddy L, Rohde C, Buchbinder S, Sia C. Hawaii's Healthy Start program of home visiting for at-risk families: evaluation of family identification, family engagement, and service delivery. Pediatrics 2000;105;250–259.

### Kempe Family Stress Inventory (KFI)

Score one point for each positive response

1 Parent history of abuse as child (beaten or deprived)
2 Parent history of criminal activity, mental illness, or substance abuse history
3 Previous or current Child Protective Services involvement
4 Parent with isolation, low self-esteem, or depression
5 Multiple stresses or crises
6 Potential for violent temper outbursts
7 Unrealistic, rigid expectations of child's behavior or development
8 Harsh punishment of child
9 Child perceived by parent to be difficult and/or provocative
10 Child unwanted or at risk for poor bonding

Item scoring for each parent: 0=no problem, 5=mild problem, 10=severe problem

positive assessment: a total score of 25 or more for either parent

Murphy S, Orkow B, Nicola RM. Prenatal prediction of child abuse and neglect: a prospective study. Child Abuse & Neglect. 1985;9(2):225–235.

Korfmacher J. The Kempe Family Stress Inventory: A review. Child Abuse & Neglect. 2000;24(1):129–140.

### Parenting Profile Assessment (PPA)

Questions directed to mother (score for item):

- Moderate to severe discipline as a child (5)
- Past or present spousal abuse (3)
- Perception of stress (4.5)
- Moderate to severe life change score (4.5)
- High school education or less (3)
- Rare involvements out of home (1.25)
- Little or no prenatal care (2.5)
- Does not feel good about herself (3.5)
- Feels like running away (3)
- Age at first birth under 20 (2)
- Unlisted or no phone (1)
- Difficulty communicating with family members (3.5)
- History of unemployment over a two-month period (of usual provider) (2)
- Currently under or unemployed (of usual provider) (2)
- Family involvements with police (2)
- Less than $20, 000 a year income (2.5)
- Curses at child(ren) when disciplining (3.5)
- Child(ren) shows evidence of punishment (3)
- Perceives discipline of children as harsh (3)
- Calls child(ren) names when disciplining (3.5)

For each “yes” answer, add scores for items. Also assess for presence of clustered items (4,5,15,16,19).

Possible risk: 21 points or more or presence of all items in cluster

Low risk: less than 21 points and not all items in cluster present

Uncertain risk: unsure of answers to questions

Anderson CL. The parenting profile assessment: screening for child abuse. Applied Nursing Research. 1993;6(1):31–38.

## Intimate Partner Violence Against Women

### The Partner Abuse Interview

“Many people, at one time or another, get physical with their partner when they're angry. For example, some people threaten to hurt their partners, some push or shove, and some slap or hit. I'm going to ask you about a variety of common behaviors, and I'd like you to tell me if your partner did these during the past year.”

For each behavior answered no, put a “zero” in the appropriate box and ask if patient was bruised or injured in any other way.

If answer is yes, code “1” for no injury, “2” for possible injury, and “3” for injury.

Has your partner... | | Yes/No | Injury Codes
1. | Thrown something at you | ( ) | 1 2 3
2. | Pushed, grabbed, or shoved you | ( ) | 1 2 3
3. | Slapped you | ( ) | 1 2 3
4. | Kicked, bit, hit you with a fist ( ) | ( ) | 1 2 3
5. | Hit or tried to hit you with an object | ( ) | 1 2 3
6. | Beat you up | ( ) | 1 2 3
7. | Threatened you with a gun or knife | ( ) | 1 2 3
8. | Used a gun or knife | ( ) | 1 2 3
9. | Forced you to have sex when you didn't want to | ( ) | 1 2 3
10. | Other | ( ) | 1 2 3
Ask the following questions if the answer to any of the above questions is anything other than “zero”
11. | “Some people are afraid that their partners will physically hurt them if they argue with their partners or do something their partners don't like. How much would you say you are afraid of this happening to you?”

( ) Not at all (1)

( ) A little (2)

( ) Quite a bit/Very afraid (3)

Pan HS, Ehrensaft MK, Heyman RE, O'Leary KD, Schwartz R. Evaluating domestic partner abuse in a family practice clinic. Family Medicine 1997;29(7):492–5.

### Screening Questions for Domestic Violence

Have you ever had any of the following; answer yes or no?

1 Has your male partner (husband, boyfriend) hit, slapped, kicked or otherwise physically hurt you?
2 If you are pregnant, has your male partner hit, slapped, kicked, pushed, or otherwise physically hurt you since you've been pregnant?
3 Has your male partner forced you to have sexual activities?
4 Are you afraid of your male partner?

A “yes” response to any question is considered positive for partner violence.

McFarlane J, Christoffel K, Bateman L, Miller V, Bullock L. Assessing for abuse: self-report versus nurse interview. Public Health Nursing 1991;8(4):245–250.

### Domestic Abuse Assessment Questionnaire

Answer yes or no

1 Have you ever been emotionally or physically abused by your partner or someone important to you?
2 Within the last year, have you been hit, slapped, kicked, or otherwise physically hurt by someone?
3 Since your pregnancy began, have you been hit, slapped, kicked, or otherwise physically hurt by someone?
4 Within the last year, has anyone forced you to have sexual activities?
5 Are you afraid of your partner or anyone else?

A “yes” response on any question is considered positive for partner violence.

Canterino JC, VanHorn LG, Harrigan JT, Ananth CV, Vintzileos AM. Domestic abuse in pregnancy: a comparison of a self-completed domestic abuse questionnaire with a directed interview. American Journal of Obstetrics and Gynecology 1999;181:1049–51.

### Abuse Assessment Screen (AAS) for use in Pregnancy

1 Have you ever been emotionally or physically abused by your partner or someone important to you? Yes No
2 Within the last year, have you been hit, slapped, kicked or otherwise physically hurt by someone? Yes No
  If yes, by whom? (circle all that apply)
  Husband Ex-husband Boyfriend Stranger Other Multiple No. of time
3 Since you've been pregnant, have you been hit, slapped, kicked or otherwise physically hurt by someone? Yes No
  If yes, by whom? (circle all that apply)
  Husband Ex-husband Boyfriend Stranger Other Multiple No. of times
  Mark the area of injury on the body map (map included).
  Score the most severe incident to the following scale:
  1 = Threats of abuse including use of a weapon
  2 = Slapping, pushing; no injuries and/or no lasting pain
  3 = Punching, kicking, bruises, cuts, and/or continuing pain
  4 = Beaten up, severe contusions, burns, broken bones
  5 = Head, internal, and/or permanent injury
  6 = Use of weapon, wound from weapon
4 Within the past year, has anyone forced you to have sexual activities?
  Yes No
  If yes, by whom? (circle all that apply)
  Husband Ex-husband Boyfriend Stranger Other Multiple No. of times
5 Are you afraid of your partner or anyone you listed above?
  Yes No

Responses are recorded on a data collection form, no other scoring information was provided.

Norton LB, Peipert JF, Zierler S, Lima B, and Hume L. Battering in pregnancy: an assessment of two screening methods. Obstetrics and Gynecology 1995;85(3):321–322.

### Partner Violence Screen (PVS)

1 Have you been hit, kicked, punched, or otherwise hurt by someone within the past year? If so, by whom?
2 Do you feel safe in your current relationship?
3 Is there a partner from a previous relationship who is making you feel unsafe now?

A “yes” response on any question is considered positive for partner violence.

Feldhaus KM, Koziol-McLain J, Amsbury HL, Norton IM, Lowenstein SR, Abbott JT. Accuracy of three brief screening questions for detecting partner violence in the emergency department. JAMA 1997;277(17): 1357–1361.

### The Hurt, Insult, Threaten, and Scream Scale (HITS)

The HITS scale is a paper-and-pencil instrument that is comprised of the following four items: “How often does your partner: physically Hurt you, Insult you or talk down to you, Threaten you with harm, and Scream or curse you?”

Patients responded to each of these items with a 5-point frequency format: never, rarely, sometimes, fairly often, and frequently. Score values could range from a minimum of 4 to a maximum of 20.

Sherin KM, Sinacore JM, Li X, Zitter RE, and Shakil A. HITS: a short domestic violence screening tool for use in a family practice setting. Family Medicine 1998;30(7):508–12.

### Emergency Department Domestic Violence Screening Questions

1 Does anyone in your family have a violent temper?
2 During an argument at home have you ever worried about your safety or the safety of your children?
3 Many women who present to the Emergency Department with similar injuries or complaints are victims of violence at home. Could this be what has happened to you?
4 Would you like to speak to someone about this?
5 Were any of the previous visits to the Emergency Department prompted by an injury or symptom suffered as a victim of violence at home?

A “yes” response to question 3 or “yes” to 1 or 2 and 4 would classify a person as being a victim of partner violence. A “yes” response to question 1 or 2 or both would classify a person as probably being a victim of partner violence. A “yes” response to question 5 would classify the person as having been a victim of partner violence.

Morrison LJ, Allan R, Grunfeld A. Improving the emergency department detection rate of domestic violence using direct questioning. Journal of Emergency Medicine 2000;19(2):117–124.

### Women's Experience with Battering (WEB) Scale

Description of how your partner makes you feel. | Agree strongly | Agree somewhat | Agree a little | Disagree a little | Disagree somewhat | Disagree strongly
1. He makes me feel unsafe even in my own home. | 6 | 5 | 4 | 3 | 2 | 1
2. I feel ashamed of the things he does to me. | 6 | 5 | 4 | 3 | 2 | 1
3. I try not to rock the boat because I am afraid of what he might do. | 6 | 5 | 4 | 3 | 2 | 1
4. I feel like I am programmed to react a certain way to him. | 6 | 5 | 4 | 3 | 2 | 1
5. I feel like he keeps me prisoner. | 6 | 5 | 4 | 3 | 2 | 1
6. He makes me feel like I have no control over my life, no power, no protection | 6 | 5 | 4 | 3 | 2 | 1
7. I hide the truth from others because I am afraid not to. | 6 | 5 | 4 | 3 | 2 | 1
8. I feel owned and controlled by him. | 6 | 5 | 4 | 3 | 2 | 1
9. He can scare me without laying a hand on me. | 6 | 5 | 4 | 3 | 2 | 1
10. He has a look that goes straight through me and terrifies me. | 6 | 5 | 4 | 3 | 2 | 1
Scoring: To score WEB scale, sum responses for items 1–10. Range of scores is 10–60. Score ≥ 20 indicates battering.

Coker AL, Pope BO, Smith PH, Sanderson M, Hussey JR. Assessment of clinical partner violence screening tools. Journal of American Medical Women's Association 2001;56:19–23.

### Index of Spouse Abuse, Partner Abuse Scale: Physical (ISA-P)

| All of the time | Most of the time | A good part of the time | Some of the time | A little of the time | Very rarely | None of the time
1. My partner pushes and shoves me around violently. | 7 | 6 | 5 | 4 | 3 | 2 | 1
2. My partner hits and punches my arms and body. | 7 | 6 | 5 | 4 | 3 | 2 | 1
3. My partner threatens me with a weapon like a gun or a knife. | 7 | 6 | 5 | 4 | 3 | 2 | 1
4. My partner beats me so hard I must seek medical help. | 7 | 6 | 5 | 4 | 3 | 2 | 1
5. My partner beats me when he drinks. | 7 | 6 | 5 | 4 | 3 | 2 | 1
6. My partner hits, punches, or kicks my face and head. | 7 | 6 | 5 | 4 | 3 | 2 | 1
7. My partner beats me in the face so badly that I'm ashamed to be seen in public. | 7 | 6 | 5 | 4 | 3 | 2 | 1
8. My partner tries to choke, strangle or suffocate me. | 7 | 6 | 5 | 4 | 3 | 2 | 1
9. My partner knocks me down and then kicks or stomps me. | 7 | 6 | 5 | 4 | 3 | 2 | 1
10. My partner throws dangerous objects at me. | 7 | 6 | 5 | 4 | 3 | 2 | 1
11. My partner has injured me with a weapon like a gun, knife or other object. | 7 | 6 | 5 | 4 | 3 | 2 | 1
12. My partner has broken one or more of my bones. | 7 | 6 | 5 | 4 | 3 | 2 | 1
13. My partner physically forces me to have sex. | 7 | 6 | 5 | 4 | 3 | 2 | 1
14. My partner badly hurts me while we are having sex. | 7 | 6 | 5 | 4 | 3 | 2 | 1
15. My partner injures my breast or genitals | 7 | 6 | 5 | 4 | 3 | 2 | 1
Scoring: Sum the responses, subtract the number of questions actually answered (n = 15) and multiply by 100, then divide by 90. Scores > 2 indicate physical interpersonal violence.

Coker AL, Pope BO, Smith PH, Sanderson M, Hussey JR. Assessment of clinical partner violence screening tools. Journal of American Medical Women's Association 2001;56:19–23.

### Woman Abuse Screening Tool (WAST)

1 In general how would you describe your relationship?
  a lot of tension some tension no tension
2 Do you and your partner work out arguments with ...
  great difficulty some difficulty no difficulty
3 Do arguments ever result in you feeling put down or bad about yourself?
  often sometimes never
4 Do arguments ever result in hitting, kicking or pushing?
  often sometimes never
5 Do you ever feel frightened by what your partner says or does?
  often sometimes never
6 Has your partner ever abused you physically?
  often sometimes never
7 Has your partner ever abused you emotionally?
  often sometimes never
8 Has your partner ever abused you sexually?
  often sometimes never

To score this instrument, the responses are assigned a number. For the first question “a lot of tension” gets a score of 1 and the other 2 get a 0. For the second question “great difficulty” gets a score of 1 and the other 2 get 0. For the remaining questions “often” gets a score of 1, “sometimes” gets a score of 2, and “never” gets a score of 3.

Brown JB, Lent B, Schmidt G, Sas G. Application of the Woman Abuse Screening Tool (WAST) and WAST-Short in the family practice setting. Journal of Family Practice 2000;49(10):896–903.

### Domestic Violence Screening Tool

1 Have you ever been threatened, hit, punched, slapped, or injured by a husband, boyfriend, or significant other you had at any point in the past?
2 Have you ever been hurt or frightened so badly by a husband, boyfriend, or significant other that you were in fear for your life?
3 Have you been hit, punched, slapped, or injured by a husband, boyfriend, or significant other within the last month?
4 Are you currently involved in a close relationship with a husband, boyfriend, or significant other?
5 Are you here today for injuries received from your husband, boyfriend, or significant other?
6 Do you often feel stressed due to fear of threats or violent behavior from your current husband, boyfriend, or significant other?
7 Has your current husband, boyfriend, or significant other ever hit, punched, slapped, or injured you?
8 Do you think it is likely that your husband, boyfriend, or significant other will hit, slap, punch, kick, or otherwise hurt you in the future?
9 Do you think you will be safe if you go back home to your husband, boyfriend, or significant other at this time?

A “yes” response to any question is considered positive for partner violence.

Furbee, PM, Sikora, R, Williams, JM, and Derk, SJ. Annals of Emergency Medicine 1998; 31(4):495–498.

## Elder Abuse and Neglect

Brief Abuse Screen for the Elderly (BASE)

Reis M, Nahmiash D. Validation of the Indicators of Abuse (IOA) screen. The Gerontologist 1998; 38(4):471–480.

### Hwalek-Senstock Elder Abuse Screening Test (HSEAST)

Violation of Personal Rights or Direct Abuse

1 Does someone else make decisions about your life - like how you should live or where you should live?
2 Does someone in your family make you stay in bed or tell you you're sick when you know you're not?
3 Has anyone forced you to do things you didn't want to do?
4 Has anyone taken things that belong to you without your OK?
5 Has anyone close to you tried to hurt you or harm you recently?
  Characteristics of Vulnerability
6 Do you have anyone who spends time with you, taking you shopping or to the doctor?
7 Are you sad or lonely often?
8 Can you take your own medication and get around by yourself?
  Potentially Abusive Situations
9 Are you helping to support someone?
10 Do you feel uncomfortable with anyone in your family
11 Do you feel that nobody wants you around?
12 Does anyone in your family drink a lot?
13 Do you trust most of the people in your family?
14 Does anyone tell you that you give them too much trouble?
15 Do you have enough privacy at home?

A response of “no” to items 6, 8, 13, and 15 and a response of “yes” to all other score in the abused direction.

Neale AV, Hwalek MA, Scott RO, Sengstock MC, Stahl C. Validation of the Hwalek-Sengstock Elder Abuse Screening Test. Journal of Applied Gerontology 1991; 10(4): 406–418.

### The Caregiver Abuse Screen (Reis-Nahmiash CASE)

Please answer the following questions as a helper or caregiver with yes or no

1 Do you sometimes have trouble making ( ___ ) control his/her temper or aggression?
2 Do you often feel you are being forced to act out of character or do things you feel bad about?
3 Do you find it difficult to manage ( ___'s) behavior?
4 Do you sometimes feel that you are forced to be rough with ( ___ )?
5 Do you sometimes feel you can't do what is really necessary or what should be done for ( ___ )?
6 Do you often feel you have to reject or ignore ( ___ )?
7 Do you often feel so tired and exhausted that you cannot meet ( ___ 's ) needs?
8 Do you often feel you have to yell at ( ___ )?

Scoring information was not provided.

Reis M. Validation of the caregiver abuse screen (CASE). Canadian Journal on Aging 1995; 14(52): 45–60.