# Appendix 1: Search Strategies

## Child Abuse Screening Instruments

Databases: MEDLINE (1995-2002), CINAHL (1995-2002), Health & Psychosocial Instruments (1985-2002)

1 exp Child Abuse/ or child abuse.mp.
2 (battered child$ or abused child$).mp.
3 violence against child$.mp.
4 school based.mp.
5 SCHOOLS, NURSERY/
6 (elementary school$1 or grade school$).mp.
7 4 or 5 or 6
8 7 and abuse$.mp
9 1 or 2 or 3 or 8
10 Mass Screening/ or screening.mp.
11 questionnaires/ or questionnaire$.tw.
12 interviews/ or interview$.tw.
13 10 or 11 or 12
14 9 and 13
15 limit 14 to (human and English language)
16 from 15 keep 1–1762

## Child Abuse Interventions

Databases: MEDLINE (1966-2002), CINAHL (1982-2002)

1 exp Child Abuse/ or child abuse.mp.
2 (battered child$ or abused child$).mp.
3 violence against child$.mp.
4 school based.mp.
5 SCHOOLS, NURSERY/
6 (elementary school$1 or grade school$).mp.
7 4 or 5 or 6
8 7 and abuse$.mp.
9 1 or 2 or 3 or 8
10 PEDIATRICS/ or pediatrics.mp.
11 pediatrician$.mp.
12 Physicians, Family/ or family physicians.mp.
13 exp Primary Health Care/ or primary care.mp.
14 Family Practice/ or family practice.mp.
15 emergencies/ or emergency.mp.
16 exp emergency service, hospital/ or emergency department$.mp.
17 10 or 11 or 12 or 13 or 14 or 15 or 16
18 9 and 17
19 pc.fs. or prevent$.mp. or intervention.mp. or assessment.mp.
20 exp counseling/ or counsel$.mp.
21 (patient education or questionnaire$).mp.
22 questionnaires/
23 interviews/ or interview$.mp.
24 exp clinical trials/ or clinical trial$.mp.
25 19 or 20 or 21 or 22 or 23 or 24
26 18 and 25
27 limit 26 to (human and English language)
28 from 27 keep 1–104

Database: PsycINFO (1984-2002)

1 exp Child Abuse/ or child abuse.mp.
2 (battered child$ or abused child$).mp.
3 violence against child$.mp.
4 (school based and (violence or abuse$)).mp.
5 exp Nursery Schools/ or nursery school.mp.
6 exp Elementary Schools/ or elementary school.mp.
7 grade school$.mp.
8 (5 or 6 or 7) and (abuse or violence).mp.
9 1 or 2 or 3 or 4 or 8
10 exp PEDIATRICS/ or pediatrics.mp.
11 exp Family Physicians/ or family physicians.mp.
12 exp Primary Health Care/ or exp Physicians/ or primary care.mp.
13 exp Family Physicians/ or family practice.mp.
14 exp emergency services/ or emergency$.mp.
15 exp School Nurses/ or school nurse.mp.
16 10 or 11 or 12 or 13 or 14 or 15
17 9 and 16
18 limit 17 to (human and english language)
19 prevention/ or prevent$.mp. or intervention.mp. or assessment.mp.
20 exp counseling/ or counsel$.mp.
21 exp Client Education/ or patient education.mp.
22 questionnaires/ or questionnaire$.mp.
23 exp INTERVIEWS/ or interviews.mp.
24 clinical trial$.mp.
25 exp At Risk Populations/ or exp Cohort Analysis/ or cohort study.mp.
26 19 or 20 or 21 or 22 or 23 or 24 or 25
27 18 and 26
28 from 27 keep 1–132

Database: ERIC (1989-2002)

1 Child Abuse
2 Family Practice
3 Physicians
4 1 and 2 or 3

Database: Cochrane Database of Systematic Reviews & Controlled Trials

Key word search: child abuse

## Intimate Partner Violence Screening Instruments

Databases: MEDLINE (1966-2002), PsycINFO (1984-2002), Health & Psychosocial Instruments (1985-2002)

1 spouse abuse/or domestic violence.mp. or battered woman.mp.
2 (screening or identity or early detection).mp.
3 questionnaires.mp.
4 physicians, family/ or “family physicians”.mp.
5 primary health care/ or “primary care”.mp.
6 family practice/or “family practice”.mp.
7 2 or 3 or 4 or 5 or 6
8 1 or 7
9 limit 8 to (human and English)

## Intimate Partner Violence Interventions

Databases: MEDLINE (1966-2002), CINAHL(1982-2002)

1 spouse abuse/ or domestic violence.mp. or battered women.mp.
2 ((intimate partner or life partner or partner or wife or husband) and (violence or abuse)).mp.
3 1 or 2
4 internal medicine.mp.
5 Physicians, Family/ or family physicians.mp.
6 exp Primary Health Care/ or primary care.mp.
7 Family Practice/ or family practice.mp.
8 EMERGENCIES/ or emergency.mp.
9 exp emergency service, hospital/ or emergency department$.mp.
10 OBSTETRICS/ or “OBSTETRICS AND GYNECOLOGY DEPARTMENT, HOSPITAL”/ or obstetrics.mp.
11 4 or 5 or 6 or 7 or 8 or 9 or 10
12 3 and 11
13 pc.fs. or prevent$.mp. or intervention.mp. or assessment.mp.
14 exp counseling/ or counsel$.mp
15 (patient education or questionnaire$).mp.
16 questionnaires/
17 interviews/ or interview$.mp.
18 exp clinical trials/ or clinical trial$.mp.
19 13 or 14 or 15 or 16 or 17 or 18
20 12 and 19
21 limit 20 to (human and English language)
22 from 21 keep 1–151

Database: PsycINFO (1984-2002)

1 exp Partner Abuse/ or spouse abuse.mp.
2 exp Battered Females/
3 exp Family Violence/ or exp Victimization/ or exp Emotional Abuse/ or battered women.mp.
4 3 and (women or females).mp.
5 ((intimate partner$ or life partner$ or partner or wife or husband) and (violence or abuse)).mp.
6 1 or 2 or 4 or 5
7 internal medicine.mp.
8 exp Family Physicians/ or family physicians.mp.
9 exp Primary Health Care/ or primary care.mp.
10 exp Family Physicians/ or family practice.mp.
11 exp emergency services/ or emergenc$.mp.
12 exp OBSTETRICS/ or obstetrics.mp.
13 exp GYNECOLOGY/ or gynecology.mp.
14 7 or 8 or 9 or 10 or 11 or 12 or 13
15 6 and 14
16 (prevent$ or intervention or assessment).mp. [mp=title, abstract, heading word, table of contents, key phrase identifiers]
17 exp counseling/ or counsel$.mp.
18 exp Client Education/ or patient education.mp.
19 questionnaires/ or questionnaire$.mp.
20 exp interviews/ or interview$.mp.
21 clinical trial$.mp.
22 exp at risk populations/ or cohort study$.mp.

## Elder Abuse Screening Instruments

Databases: MEDLINE (1966-2002), PsycINFO (1984-2002), Health & Psychosocial Instruments (1985-2002)

1 elder abuse.mp.
2 (domestic violence or family violence).mp.
3 (elder$ or aged or old or ageing).mp.
4 (vulnerable or disabled or handicapped).mp.
5 (2 or 4) and 3
6 1 or 5
7 mass screening/ or screening.mp.
8 questionnaires/ or questionnaire$.tw.
9 interview/ or interview$.tw.
10 7 or 8 or 9
11 6 and 10
12 limit 11 to (human and English language)
13 from 12 keep 1–1009

Database: AARP Ageline (1978-2002)

1 elder abuse.mp. [mp=title, abstract, descriptors, identifiers]
2 ((family or domestic) and (abuse or violence)).mp.
3 (elder$ or old or ageing or aging or aged or geriatric).mp.
4 2 and 3
5 1 or 4
6 (internal medicine or geriatrics or family physicians or family practice).mp. [mp=title, abstract, descriptors, identifiers]
7 (primary care or emergency or emergency services).mp. [mp=title, abstract, descriptors, identifiers]

## Elder Abuse Interventions

Databases: MEDLINE (1966-2002), CINAHL (1982-2002)

1 elder abuse.mp.
2 (domestic violence or family violence).mp.
3 (elder$ or aged or old or ageing).mp.
4 2 and 3
5 (vulnerable or disabled or handicapped).mp.
6 1 or 4 or 5
7 GERIATRICS/ or geriatrics.mp.
8 Internal Medicine/ or internal medicine.mp.
9 Physicians, Family/ or family physicians.mp.
10 exp Primary Health Care/ or primary care.mp.
11 Family Practice/ or family practice.mp
12 EMERGENCIES/ or emergency.mp.
13 exp Emergency Service, Hospital/ or emergency department.mp.
14 7 or 8 or 9 or 10 or 11 or 12 or 13
15 6 and 14
16 limit 15 to (human and English language)
17 pc.fs. or prevent$.mp. or intervention.mp. or assessment.mp.
18 exp COUNSELING/ or counseling.mp.
19 patient education.mp.
20 questionnaires.mp.
21 QUESTIONNAIRES/
22 INTERVIEWS/ or interviews.mp.
23 exp clinical trials/ or clinical trial$.mp.
24 17 or 18 or 19 or 20 or 21 or 22 or 23
25 16 and 24
26 from 25 keep 1–129

Database: PsycINFO (1984-2002)

1 elder abuse.mp.
2 (domestic violence or family violence).mp.
3 (elder$ or aged or aging or ageing or old or geriatric).mp.
4 (vulnerable or disabled or handicapped).mp.
5 3 or 4
6 2 and 5
7 1 or 6
8 exp GERIATRICS/ or geriatrics.mp.
9 internal medicine.mp. or exp Physicians/
10 exp Family Physicians/ or family physicians.mp.
11 exp Primary Health Care/ or primary care.mp.
12 exp Family Physicians/ or exp General Practitioners/ or family practice.mp.
13 exp emergency services/ or emergency$.mp.
14 8 or 9 or 10 or 11 or 12 or 13
15 7 and 14
16 limit 15 to (human and English language)
17 prevention/ or prevent$.mp. or intervention.mp. or assessment.mp.
18 exp counseling/ or counsel$.mp. or assess$.mp.
19 exp Client Education/ or patient education.mp.
20 questionnaires/ or questionnaire$.mp.
21 exp interviews/ or interview$.mp.
22 clinical trial$.mp.
23 exp at risk populations/ or exp cohort analysis/ or cohort stud$.mp.
24 17 or 18 or 19 or 20 or 21 or 22 or 23
25 16 and 24
26 from 25 keep 1–36

Database: AARP Ageline (1978-2002)

1 elder abuse.mp. [mp=title, abstract, descriptors, identifiers]
2 ((family or domestic) and (abuse or violence)).mp.
3 (elder$ or old or ageing or aging or aged or geriatric).mp.
4 2 and 3
5 1 or 4
6 (internal medicine or geriatrics or family physicians or family practice).mp. [mp=title, abstract, descriptors, identifiers]
7 (primary care or emergency or emergency services).mp. [mp=title, abstract, descriptors, identifiers]
8 6 or 7
9 5 and 8
10 from 9 keep 1–75