# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
2 Feightner JW. Routine preschool school screening for visual and hearing problems. In: The Canadian Task Force on the Periodic Health Examination. The Canadian Guide to Clinical Preventive Health Care. Ottawa, Canada: Canada Communication Group; 1994:297–304.
3 Schmidt P. Current screening programs. In: Vision Screening in the Preschool Child. Proceedings of a Conference held in Bethesda, Md., 10–11 September 1998. New York, NY: Lighthouse International; 1998:129–164.
4 Statement of purpose. In: Vision Screening in the Preschool Child. Proceedings of a Conference held in Bethesda, Md., 10–11 September 1998. New York, NY: Lighthouse International; 1998:1–2.
5 Hartmann EE, Dobson V, Hainline L, et al. Preschool Vision Screening: Summary of a Task Force Report on Behalf of the Maternal and Child Health Bureau and the National Eye Institute Task Force on Vision Screening in the Preschool Child. Pediatrics. 2000;106:1105-1116. [pmid: 11061783].
6 Snowdon SK, Stewart-Brown SL. Preschool Vision Screening: Results of a Systematic Review. York, U.K.: The University of York and NHS Centre for Reviews and Dissemination and Health Services Research Unit, Department of Public Health and Primary Care, University of Oxford; 1997.
7 Williams C, Harrad RA, Sparrow JM, Harvey I, Golding J. Future of preschool vision screening. Conclusions for or against services are invalid without appropriate research evidence. BMJ. 1998;316:937. [pmid: 9569402].
8 Simons K. Preschool vision screening: rationale, methodology and outcome. Surv Ophthalmol. 1996;41:3-30. [pmid: 8827927].
9 Flynn JT, Cassady JC. Current trends in amblyopia therapy. Ophthalmology. 1978;85:429-459.
10 Levi DM, Carkeet A. Amblyopia: A consequence of abnormal visual development. In: Simons K. Early Visual Development, Normal and Abnormal. New York, NY: Oxford University Press; 1993:391–408.
11 Keech RV, Kutschke PJ. Upper age limit for the development of amblyopia. J Pediatr Ophthalmol Strabismus. 1995;32:89-93. [pmid: 7629676].
12 Moore B, Lyons SA, Walline J. The Hyperopic Infants' Study Group: A Clinical Review of Hyperopia in Young Children. J Optometric Assoc. 1999;70:215-224.
13 Brown NP, Koretz JF, Bron AJ. The development and maintenance of emmetropia. Eye. 1999;13:83-92. [pmid: 10396390].
14 Ehrlich DL, Braddick OJ, Atkinson J, Anker S, et al. Infant emmetropization: longitudinal changes in refraction components from nine to twenty months of age. Optometry Vision Science. 1997;74:822-843.
15 Marsh-Tootle W. Types of screening: currently available technologies. In: Vision Screening in the Preschool Child. Proceedings of a Conference Held in Bethesda, Md., 10–11 September 1998. New York, NY: Lighthouse International; 1998:97–128.
16 Simons K. Photoscreening. Ophthalmology. 2000;107:1619-1620. [pmid: 10964816].
17 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3):21-35. [pmid: 11306229].
18 Kohler L, Stigmar G. Visual disorders in 7-year-old children with and without previous vision screening. Acta Paediatr Scand. 1978;67:373-377. [pmid: 654915].
19 Preslan MW, Novak A. Baltimore vision screening project. Ophthalmology. 1996;103:105-109. [pmid: 8628540].
20 Preslan MW, Novak A. Baltimore Vision Screening Project. Phase 2. Ophthalmology. 1998;105:150-153. [pmid: 9442791].
21 Jakobsson P, Kvarnstrom G, Lennerstrand G. Amblyopia in Sweden: Effects of screening at health care centers and in school. In: Spiritus M. Transactions, 23rd Meeting of the European Strabismological Association. New York, NY: Aeolus Press; 1997:25–30.
22 Vinding T, Gregersen E, Jensen A, Rindziunski E. Prevalence of amblyopia in old people without previous screening and treatment. An evaluation of the present prophylactic procedures among children in Denmark. Acta Ophthalmol (Copenh). 1991;69:796-798. [pmid: 1789098].
23 Attebo K, Mitchell P, Cumming R, Smith W, Jolly N, Sparkes R. Prevalence and causes of amblyopia in an adult population. Ophthalmology. 1998;105:154-159. [pmid: 9442792].
24 Kemper AR, Margolis PA, Downs SM, Bordley WC. A systematic review of vision screening tests for the detection of amblyopia. Pediatrics. 1999;104:1220-1222. [pmid: 10545578].
25 Kennedy R, Sheps SB, Bagaric D. Field trial of the Otago photoscreener. Can J Ophthalmol. 1995;30:193-7. [pmid: 7585311].
26 Cogen MS, Ottemiller DE. Photorefractor for detection of treatable eye disorders in preverbal children. Ala Med. 1992;62:16-20. [pmid: 1442456].
27 Morgan K, Johnson W. Clinical evaluation of a commercial photorefractor. Arch Ophthalmol. 1987;105:1528-1531. [pmid: 3675285].
28 Ottar WL, Scott WE, Holgado SI. Photoscreening for amblyogenic factors. J Pediatr Ophthalmol Strabismus. 1995;66:429-434.
29 Tong PY, Enke-Miyazaki E, Bassin RE, et al. Screening for amblyopia in preverbal children with photoscreening photographs. National Children's Eye Care Foundation Vision Screening Study Group. Ophthalmology. 1998;105:856-863. [pmid: 9593387].
30 Tong PY, Bassin RE, Enke-Miyazaki E, et al. Screening for amblyopia in preverbal children with photoscreening photographs II. Sensitivity and specificity of the MTI Photoscreener. Ophthalmology. 2000;107:1623-1629. [pmid: 10964818].
31 Cooper CD, Gole GA, Hall JE, Colville DJ, Carden SM, Bowling FG. Evaluating photoscreeners II: MTI and Fortune. Aust NZ J Ophthalmol. 1999;27:387-398.
32 Robinson B, Bobier WR, Martin E, Bryant L. Measurement of the validity of a preschool vision screening program. Am J Public Health. 1999;89:193-198. [pmid: 9949748]. [pmcid: 1508544].
33 Birch EE, Fawcett S, Stager DR. Why does early surgical alignment improve stereoacuity outcomes in infantile esotropia?. J AAPOS. 2000;4:10-14. [pmid: 10675865].
34 Ingram RM, Arnold PE, Dally S, Lucas J. Results of a randomised trial of treating abnormal hypermetropia from the age of 6 months. Br J Ophthalmol. 1990;74:158-159. [pmid: 2182103]. [pmcid: 1042038].
35 Cheng KP, Hiles DA, Biglan AW, Pettapiece MC. Visual results after early surgical treatment of unilateral congenital cataracts. Ophthalmology. 1991;98:903-910. [pmid: 1866144].
36 Simons K, Preslan M. Natural history of amblyopia untreated owing to lack of compliance. Br J Ophthalmol. 1999;83:582-587. [pmid: 10216059]. [pmcid: 1723047].
37 Eibschitz-Tsimhoni M, Friedman T, Naor J, Eibschitz N, Friedman Z. Early screening for amblyogenic risk factors lowers the prevalence and severity of amblyopia. J AAPOS. 2000;4:194-1999. [pmid: 10951293].
38 Eustis HS, Chamberlain D. Treatment for amblyopia: results using occlusive contact lens. J Pediatr Ophthalmol. 1996;33:319-322.
39 Krumholtz I, FitzGerald D. Efficacy of treatment modalities in refractive amblyopia. J Am Optom Assoc. 1999;70:399-404. [pmid: 10437342].
40 Bowman RJ, Williamson TH, Andrews RG, Aitchison TC, Dutton GN. An inner city preschool visual screening programme: long-term visual results. Br J Ophthalmol. 1998;82:543-548. [pmid: 9713063]. [pmcid: 1722604].
41 Latvala ML, Paloheimo M, Karma A. Screening of amblyopic children and long-term follow-up. Acta Ophthalmol Scand. 1996;74:488-492. [pmid: 8950400].
42 Beardsell R, Clarke S, Hill M. Outcome of occlusion treatment for amblyopia. J Pediatr Ophthalmol. 1999;36:19-24.
43 Hiscox F, Strong N, Thompson JR, Minshull C, Woodruff G. Occlusion for amblyopia: a comprehensive survey of outcome. Eye. 1992;6:300-304. [pmid: 1446765].
44 Woodruff G, Hiscox F, Thompson JR, Smith LK. Factors affecting the outcome of children treated for amblyopia. Eye. 1994;8:627-631. [pmid: 7867817].
45 Newman DK, Hitchcock A, McCarthy H, Keast-Butler J, Moore AT. Preschool vision screening: outcome of children referred to the hospital eye service. Br J Ophthalmol. 1996;80:1077-1082. [pmid: 9059274]. [pmcid: 505707].
46 Repka MX, Ray JM. The efficacy of optical and pharmacological penalization. Ophthalmology. 1993;100:769-774. [pmid: 8493022].
47 Rutstein RP, Fuhr PS. Efficacy and stability of amblyopia therapy. Optom Vis Sci. 1992;69:747-754. [pmid: 1436994].
48 Epelbaum M, Milleret C, Buisseret P, Dufier JR. The sensitive period for strabismic amblyopia in humans. Ophthalmology. 1993;100:323-327. [pmid: 8460000].
49 Simons K, Stein L, Sener EC, Vitale S, Guyton DL. Full-time atropine, intermittent atropine, and optical penalization and binocular outcome in treatment of strabismic amblyopia. Ophthalmology. 1997;104:2143-2155. [pmid: 9400777].
50 Bradford GM, Kutschke PJ, Scott WE. Results of amblyopia therapy in eyes with unilateral structural abnormalities. Ophthalmology. 1992;99:1616-1621. [pmid: 1454331].
51 Stewart-Brown S, Haslum MN, Butler N. Educational attainment of 10-year-old children with treated and untreated visual defects. Dev Med Child Neurol. 1985;27:504-513. [pmid: 4029521].
52 Packwood EA, Cruz OA, Rychwalski PJ, Keech RV. The psychosocial effects of amblyopia study. J AAPOS. 1999;3:15-17. [pmid: 10071896].
53 Tommila V, Tarkkanen A. Incidence of loss of vision in the healthy eye in amblyopia. Br J Ophthalmol. 1981;65:575-577. [pmid: 7295619]. [pmcid: 1039584].
54 Ingram RM, Arnold PE, Dally S, Lucas J. Emmetropisation, squint, and reduced visual acuity after treatment. Br J Ophthalmol. 1991;75:414-416. [pmid: 1854694]. [pmcid: 1042408].
55 Feldman W, Sackett B, Milner RA, Gilbert S. Effects of preschool screening for vision and hearing on prevalence of vision and hearing problems 6–12 months later. Lancet. 1980;8202:1014-1016. [pmid: 6107638].
56 Donahue SP, Johnson TM, Leonard-Martin TC. Screening for amblyogenic factors using a volunteer lay network and the MTI Photoscreener: initial results from 15,000 preschool children in a statewide effort. Ophthalmology. 2000;107:1637-1644. [pmid: 10964820].
57 DeBecker I, MacPherson HJ, LaRoche GR, et al. Negative predictive value of a population-based preschool vision screening program. Ophthalmology. 1992;99:998-1003. [pmid: 1630790].
58 Hered RW, Murphy S, Clancy M. Comparison of HOTV and Lea Symbols charts for preschool vision screening. J Pediatr Ophthalmol Strabismus. 1997;34:24-28. [pmid: 9027676].
59 Lewis RC, Marsh-Tootle WL. The reliability of interpretation of photoscreening results with the PS-100 in Headstart preschool children. J Am Optom Assoc. 1995;66:429-434. [pmid: 7560731].
60 Williams C, Harrad RA, Harvey I, Frankel S, Golding J. Methodology for a randomised controlled trial of preschool vision screening. A new approach with the ‘ALSPAC’ project. Ophthalmic Epidemiol. 1996;3:63-76. [pmid: 8841058].
61 Ciner EB, Schmidt PP, Orel-Bixler D, et al. Vision screening of preschool children: Evaluating the past, looking toward the future. Optom Vis Sci. 1998;75:571-584. [pmid: 9734801].