# Acknowledgments

We acknowledge the assistance at AHRQ of Jacqueline Besteman, J.D., M.A., EPC Program Officer; David Atkins, M.D., M.P.H., Director, Clinical Prevention Program and Dana Best, MD, the AHRQ Task Officer. We extend our appreciation as well to RTI-UNC EPC staff, including Kathleen N. Lohr, PhD, co-director of the EPC's Clinical Prevention Center; Sonya Sutton, BSPH, and Sheila White, of Research Triangle Institute.

## Request for Reprints

Reprints are available from the AHRQ Web site at www.ahrq.gov (click on Preventive Services) and in print through the AHRQ Publications Clearinghouse (call 1-800-358-9295).