# Evidence Tables

Evidence Table 1. Key Question 1: Prevalence of Visual Impairment

Source: Author, Year | Research Design | Subjects | Measurements | Results | Quality*
Kohler & Stigmar, 1978^18^ | Cross-sectional | 2,173 seven year old children in Sweden were screened, those with worse than 20/20 vision were referred to an ophthalmologist | Complete eye exam | 310 children were referred (14.2% of total population); 5.8% of these children had amblyopia (0.8% of total population); 6.1% of referred group needed glasses; of the 40 with significant visual impairment, 29/40 did not have previous vision screening and 11/40 screened normal at 4 years of age; the risk of finding a new significant eye disorder in a school entrant was more than 6 times greater for a child who was not examined in his preschool years, and the risk of finding an amblyopic child was more than 10 times greater | N/A
Vinding et al., 1991^22^ | Cross-sectional | 1000 adults in Denmark between 60–80 years old | Complete eye exam | 2.9% of the population had amblyopia | N/A
Preslan & Novak, 1996^19^ | Cross-sectional | 680 children were recruited from an inner city school system; 75% of these children were between preschool and second grade | Complete eye exam | 173/680 (25.4%) of these children failed initial vision screening. 76 of those who failed did not pass a second screening; 3.9% of the children that failed two screening exams had amblyopia; the etiology for the amblyopia included strabismus (44%), spherical anisometropis (26%), astigmatic anisometropia (18%), and bilateral ametropia (12%); overall, 8.3% were found to have refractive errors requiring correction | N/A
Jakobsson et al., 1997^21^ | Retrospective cohort | All children (3,126) born in 1982 in 3 swedish communities | Visual acuity screening at age 4 to 5.5 years of age, 7 years of age, and 10 years of age | Prevalence of amblyopia at 10 yrs was 0.03% | Good
Attebo et al., 1998^23^ | Cross-sectional | In Australia, 3654 persons>49 years | Complete eye exam | 3.2% of the population was found to have amblyopia; of the 118 with amblyopia, 9 were unaware that they had a visual impairment | N/A
Preslan & Novak, 1998^20^ | Cross-sectional | 2,285 preschool children in inner city schools | Complete eye exam | 5.3% of the children had amblyopia and 12.5% of the children had refractive errors, the cause of the amblyopia was equally divided between strabismus, anisometropia, and astigmatism | N/A

* N/A = Not applicable.

Evidence Table 2. Key Question 2: Screening Test Performance

Source: Author, Year | Research Design | Subjects | Measurements | Results | Quality
Tong et al., 1998^29^ | Cross-sectional | 103 children between 1 and 44 months of age seen in an ophthalmology clinic and screened with the MTI Photoscreener™ | Complete eye exam | The prevalence of visual disorder was 74%; depending on the reader of the photograph, the sensitivity ranged from 37% to 88%; the range of specificity was 40% to 88%; no single reader had both sensitivity and specificity >70% | Poor
Tong et al., 2000^30^ | Cross-sectional | 392 children younger than 3 years old in an ophthalmology clinic screened with the MTI Photoscreener™ | Complete eye exam | The prevalence of visual impairment was 43%; the range of test sensitivity was 56 to 65%; specificity 87 to 91% | Poor
Cooper et al., 1999^31^ | Cross-sectional | 105 children between 12 and 44 months old seen in an ophthalmology clinic screened with the MTI Photoscreener™ | Complete eye exam | The prevalence of visual impairment was 60%. One photograph reader had a sensitivity of 56% and specificity of 79%. Another reader had a sensitivity of 61% and specificity of 86% | Poor
Kemper et al., 1999^24^ | Systematic review (Includes ^22,^ ^23,^ ^24^) | 3 studies that met inclusion criteria for the USPSTF review | Complete eye exam | Titmus stereotest and either Snellen E or stycar graded balls: pop. prevalence= 6%, sensitivity between 9% and 12.5%, specificity= 99%; Visiscreen 100TM: pop prevalence= 60%, sensitivity= 85%, specificity= 94%; Visiscreen 100TM: pop. prevalence= 12%, sensitivity= 91%, specificity= 74%. | Good Systematic Review
Robinson et al., 1999 ^32^ | Cross-sectional | 3,434 kindergartenters screened with either Cambridge Crowding cards and Hirschberg test, or cards, Hirschberg and Stereofly, or cards and stereofly | Complete eye exam on all who failed and sample of passes | sensitivity ranged from 60 to 84% and specificity 65–80%. See article for detailed sens and spec data | Fair

Evidence Table 3. Key Question 3: Early Detection of Amblyogenic Factor

Source: Author, Year | Research Design | Subjects | Measurements | Results | Quality
Cheng et al., 1991^35^ | Retrospective cohort | 25 infants with unilateral cataracts, 7 of whom also had strabismus, corrected before 1 year of age and then treatment for amblyopia | Visual acuity five years later | 20% had visual acuity of least 20/40; the best results were achieved for those treated before 17 weeks of age | Fair
Birch et al., 2000^33^ | Prospective cohort | 129 children with esotropia treated by 5 to 24 months of age with surgery | Stereopsis at 5 to 9 years of age | 36.4% had stereopsis | Fair
Ingram et al., 1990^34^ | RCT | 371 6 months old with hyperopia | Dilated eye exam (unmasked) up to every 3 months and at age 3.5 years | 24% in both groups developed strabismus | Poor

Evidence Table 4. Key Question 4: Treatment of Amblyopia

Source: Author, Year | Research Design | Subjects | Measurements | Results | Quality
Bradford et al., 1992^50^ | Retrospective cohort | 15 patients treated at University of Iowa between 1970 and 1989 for media opacity and amblyopia, average age unclear, treated with occlusion therapy | Visual acuity | 87% of subjects achieved 20/40 or better | Poor
Hiscox et al., 1992^43^ | Retrospective cohort | 368 patients with an average age of 4 years 7 months with amblyopia identified by a screening program in England | Visual acuity | 40% achieved at least 20/30 vision; improvement was similar across all age groups | Fair
Rutstein & Fuhr, 1992^47^ | Retrospective cohort | 64 subjects, with an average age of 9 years, with amblyopia from anisometropia or strabismus treated with occlusion | Improvement in visual acuity | Of the subjects treated by 7 years of age, 90% showed some acuity gain; of those treated after 8 years of age, 77% showed some gain in visual acuity; at least 67% of those with amblyopia (18 subjects total) followed for 1 year lost some of the acuity gain after cessation of therapy | Fair
Epelbaum et al., 1993^48^ | Retrospective cohort | 407 children with strabismic amblyopia in France who were treated by, on average, 57 months of age | Decrease in visual acuity difference between the two eyes | Of those subjects who began treatment by 21 months of age, 70% showed improvement; if treatment is begun between 28 and 33 months of age, 95% improve; around 144 months of age, treatment does not lead to improvement | Fair
Repka & Ray, 1993^46^ | Retrospective cohort | 166 children with amblyopia treated for 3 months with either optical (87 subjects, average age 6.2 years) or pharmocological penalization (88 subjects, average age 5.3 years) | Improvement in visual acuity | Of those treated with optical penalization, 77% improved by the end of treatment; of those treated with pharmocologic penalization, 76% improved by the end of treatment | Fair
Woodruff et al., 1994^44^ | Retrospective cohort | 961 subjects with amblyopia treated in England | Visual acuity | 48% of the subjects had at least 20/30 vision at the end of treatment | Fair
Eustis & Chamberlin, 1996^38^ | Prospective cohort | 25 patients aged 2.5–9.5 years with amblyopia treated with opaque contact lenses | Lines of visual acuity or octaves of improvement | 92% improved | Fair
Latvala et al., 1996^41^ | Prospective cohort | 72 children with amblyopia treated and followed up, on average, 9 years later | Visual acuity | 96% of the subjects had at least 20/40 vision bilaterally at follow-up; of those children referred before 4 years of age, 97% had better than 20/30 vision; of the older children, 86% had better than 20/30 vision | Fair
Newman et al., 1996^45^ | Retrospective cohort | 91 children with amblyopia, 43 of which had strabismus, referred by a preschool vision program in England | Visual acuity | By the end of therapy, which took, on average 7.7 years, 87% of the subjects with amblyopia not associated with strabismus had at least 20/30 vision; 64.3% of those with strabismic amblyopia had at least 20/30 vision | Fair
Simons et al., 1997^49^ | Retrospective cohort | 163 patients with strabismic amblyopia, treated with atropine (38 subjects, average age 5.4 y), intermittent atropine (73 subjects, average age 6.1 y), or optical penalization (52 subjects, 6.1 y) | Binocular vision | 95% of the subjects in the atropine group, 89% of intermittent atropine group, and 77% of optical penalization group had binocular vision | Fair
Bowman et al., 1998^40^ | Prospective cohort | 87 subjects with amblyopia who were initially detected by, on average 4.1 years, received treatment until, on average 7.5 years, and then followed up, on average, at 12.3 years of age | Improvement in visual acuity | 83% of the subjects improved by completion of therapy; 79% mainained or improved visual acuity by follow-up | Fair
Beardsell et al., 1999^42^ | Retrospective cohort | 246 children with amblyopia (68% with strabismus, 32% with anisometropia) treated with occlusion | Visual acuity | Of those with esotropia, 85% had at least 20/30 vision, with anisometropia, 95% had at least 20/30 vision | Fair
Krumholtz & FitzGerald, 1999^39^ | Prospective cohort | 52 children younger than 14 yr old with refractive amblyopia treated with either optical correction(17 subjects), optical correction and patching(23 subjects), or vision therapy (12 subjects) and followed for 6 months | Improvement in visual acuity | Overall, optical treatment resulted in 41% improvement; optical treatment and patching led to 69% improvement; vision therapy led to 67% improvement; of those children 2 yrs to 5yrs 11 months, 45% (5 out of 11 subjects) had improvement | Fair

Evidence Table 5. Key Question 5: Treatment of Non-amblyopiagenic Visual Impairment

Source: Author, Year | Research Design | Subjects | Measurements | Results | Quality
Newman et al., 1996^45^ | Retrospective cohort | 100 children in England with refractive error but without amblyopia or strabismus | Visual acuity | 98% of the children improved to at least 20/20 in the corrected eye. 2% achieved 20/30 in the corrected eye | Fair

Evidence Table 6. Key Question 6: Health Outcomes

Source: Author, Year | Research Design | Subjects | Measurements | Results | Quality
Tommila & Tarkkanen, 1981^53^ | Identification of cases and comparison to total population | 23 subjects from Finland with amblyopia who had lost vision in the sound eye during the previous 20 years | Rate of vision loss | Risk of vision loss in healthy eye is 1.75+-.30/1000 compared to an estimated 0.66/1000 in the general population | Poor
Stewart-Brown et al., 1985^51^ | Cross-sectional | 12,905 10 year old children in England | British Ability Scales. This test has a mean score of 100 points and standard devation of 15 points | Average score for children with amblyopia was 98.4 (p<0.01) | Good
Packwood et al., 1999^52^ | Cross-sectional survey | 45 adults with amblyopia, but without strabismus, were recruited from a university-based ophthalmology clinic; there were 25 respondents | New and previously unvalidated survey | The respondents reported that amblyopia interferes with school (52%) and work (48%); furthermore, amblyopia affects lifestyle (50%), ability to participate in sports(40%), and influences job choice (36%); the respondents reported worrying about losing better eye (24%); 76% reported that amblyopia affects their self image (76%) | Poor

*N/A = Not applicable.

Evidence Table 7. Key Question 8: Adverse Effects of Treatment

Source: Author, Year | Research Design | Subjects | Measurements | Results | Quality
Epelbaum et al., 1993^48^ | Retrospective cohort | 407 children in France with strabismic amblyopia beginning teatment on average at 57 months | Visual acuity in occluded eye | Mean magnitude of decrease of occluded eye during treatment was 20/182. Decrease was not permanent and almost always resolved in a few weeks | Fair
| | | | Decrease was not permanent and almost always resolved in a few weeks
Ingram et al., 1991 ^54^ | RCT | 287 children from previous study of treatment for hyperopia at 6 months of age | Dilated Eye exam at 3.5 years (unmasked) | Emmetropization did not occur in 42% of children not given spectacles, compared to 31% of those not given spectacles | Poor