# Discussion

Visual impairment is common, affecting 5% to 10% of children under 5 years of age. No prospective randomized trial has evaluated the impact of vision screening among children. This review suggests that there are a different set of screening considerations for children less than 3 years and those who are 3-years to 5 years.

## Children Younger Than Age 3 Years

Early detection of cataracts and strabismus leads to improved outcome. Few data support early treatment of refractive errors. Although uncontrolled studies suggest that early initiation of treatment for amblyopia results in improved outcomes, there is at least a theoretical concern that early correction of refractive error can interfere with the normal development of the eye.

Components of the physical examination, such as red reflex examination, the cover test, or the Hirschberg test, can screen for cataracts and strabismus. We were unable to find any studies of the accuracy of the physical examination for the detection of visual impairment. Newer screening technology can detect cataracts, strabismus, and refractive error. The reports of the accuracy of the new screening tests are promising, but no evaluation has been done in the primary care practice setting with the tests administered as would be done by those usually responsible for screening. Additionally, little is known about how these new tests compare to the physical examination itself.

## Children Aged 3 to 5 Years

Detection of amblyopia or those conditions associated with amblyopia is important during the preschool years because treatment for amblyopia is more difficult and eventually ineffective with increasing age. A potential harm of the treatment of amblyopia is a transient decrease in visual acuity in the non-amblyopic eye.

Treatment of refractive error is usually successful. Furthermore, treatment of refractive errors is unlikely to interfere with the development of the eye after 3 years of age.

Although the new automated screening devices can potentially make screening easier, it should be recognized that these tests screen for visual acuity and amblyopia indirectly, by detecting associated conditions such as refractive errors and strabismus. Little is known about the performance of these new tests or of traditional vision screening in the primary care practice setting.

## Limitations of this Analysis

This review has several limitations related to the types of evidence that we included. First, we did not consider animal data. The previous Task Force found that animal models provide fair evidence that early intervention improves the prognosis for children with amblyopia and strabismus.^1^

Second, studies that we excluded did not meet high standards. Although this strategy minimizes potential bias, we may still have excluded important studies. For example, this review did not consider studies that lacked a clearly defined gold standard eye examination. Both the previous Task Force and the Canadian Task Force on Preventive Health Services considered a study that evaluated the impact of preschool vision screening on the prevalence of visual disorders 6 to 12 months later.^55^ This study compared the prevalence in 2 cohorts of children; one received preschool vision screening, and the other did not. Of the children in the screened cohort, 10% had a visual impairment as did 15% in the unscreened cohort. However, the diagnosis of visual impairment was based on a screening test, the Illiterate E chart, not a complete eye examination. This may also account for the high prevalence found in this study.

Our review also did not consider studies of screening tests that reported only positive or negative predictive value. Examples of these include a report that photoscreening has a positive predictive value of 84% for the diagnosis of strabismus and a study of traditional vision screening that found a negative predictive value of 98%.^56,^ ^57^ We omitted these studies because we believed that understanding the tradeoffs between sensitivity and specificity was important. Similarly, we did not consider studies that evaluated the feasibility and reliability of these screening tests.^58,^ ^59^ Although these are important factors when choosing a screening strategy, in our view establishing test accuracy is the first important step.

## Recommendations for Future Research

A randomized trial of preschool vision screening is unlikely ever to be conducted. Other study designs, however, can improve the available evidence regarding the effectiveness of screening and demonstrate the features of a successful screening strategy. Visual impairment is an active field of research, and some of these studies are under way. This section reviews some studies currently in progress and suggests studies that, if performed, could help clarify some of these important issues.

The Amblyopia Treatment Study, funded by the National Institutes of Health, is a prospective randomized trial to compare the relative effectiveness of occlusion and penalization in the treatment of amblyopia. This study may provide a standard of treatment for preschool-aged children with amblyopia.

Interest is growing in the impact of vision screening on children younger than preschool age. A study in England is evaluating the impact of frequent eye examinations by an orthoptist before 3 years of age.^60^ Outcome will be assessed by a “gold standard” ophthalmologic examination at 37 months.

Few data are available regarding the performance of vision screening tests in the primary care setting. The Eye Screening Project, now in development, will compare various commercially available screening tests in children ages 12 to 18 months and 36 to 60 months (Alex Kemper, MD, MPH, MS, personal communication, December 2000). Evaluation will occur in a pediatric office-based network. Selected children will receive a standardized diagnostic evaluation by an eye care specialist.

Photoscreening is an emerging technology. New devices are likely to be developed. As they are tested, we will gain a better understanding of the role of the currently available and newer devices.

The Vision in Preschoolers (VIP) Study Group has received pilot funding from the National Eye Institute to develop a protocol to assess preschool vision screening guidelines.^61^ This group will also develop a protocol to evaluate the performance of lay screeners teamed with health professionals to screen preschoolers at high risk for visual impairment.

A population-based case-control study could evaluate the effectiveness of current screening programs. If screening and treatment reduce future visual impairment incidence or severity, fewer of the cases with visual impairment should have been screened and treated than controls without visual impairment. A similar strategy can be used to assess the impact of visual impairment on learning and education.

Little is known about the harms of false-positive screening, wearing glasses, or having an eye patched. Focus groups and surveys could be carried out to identify such adverse effects and understand their duration and severity.