# Results

## Key Question 1: Prevalence of Visual Impairment

Most data regarding the prevalence of visual impairment had been gathered as part of the assessment of screening tests, in which those who failed the screening examination were referred for further diagnostic evaluation. This strategy can underestimate the true prevalence because a person with a false-negative screening result will not be included. We were particularly interested in the prevalence in the general population and so excluded studies that could not be generalized to a defined population.

We found studies that evaluated elementary school-aged children 18–21 and adults^22,^ ^23^ (Evidence Table 1). We included studies of the prevalence of amblyopia in adults because untreated amblyopia is thought to persist through adulthood and amblyopia must first develop in childhood.

The overall prevalence of visual impairment, including all refractive errors, is 7% to 8.2%. The prevalence of amblyopia is 2.9% to 3.9%.

## Key Question 2: Accuracy of Screening Tests

We established inclusion and exclusion criteria to select only high-quality studies of vision screening tests for children less than 5 years of age. We used 4 criteria: (1) all or a random sample of those who passed and all those who failed the screening test must receive a formally described “gold standard” eye examination; (2) the person performing the examination must be masked to the outcome of screening; (3) the criteria for failing the screening examination must be described; and (4) the test must be commercially available. Because the goal of screening is to detect children who have visual impairment, we considered only evidence that reported results in which individual children was the unit of analysis, not individual eyes.

One systematic review,^24^ which used these criteria to assess vision screening tests for children ages 2 to 5 years of age, identified 4 articles.^25^–^28^ However, we excluded 1 of these articles from our review because the study may not have been adequately masked.^28^ Our search identified 3 additional studies that evaluated children less than 3 years of age (Evidence Table 2)^29^–^31^ and 1 additional study that evaluated children over 3 years of age.^32^

None of the articles that met our inclusion criteria evaluated the role of screening for family history or parental concern. Similarly, none of the articles evaluated the accuracy of the physical examination to detect visual impairment such as cataracts or strabismus. None of the studies was performed in the primary care practice settings using usual screening procedures.

Accuracy of Screening Tests in Children Younger than Age 3 Years. We found 3 studies of the MTI photoscreener™ that evaluated young children (Table 4). The first included 103 children younger than 3 years of age.^29^ Of these, 74% had visual impairment. Eighteen volunteers, none of whom had previous experience with photoscreening, evaluated the photographs. From these readers, the sensitivity ranged from 37% to 88% and the specificity ranged from 40% to 88%. No single reader achieved sensitivity and specificity greater than 70%. The average condition specific sensitivities were 6% for cataract, 65% for refractive error, and 39% for strabismus.

Table 4 Accuracy of Screening Tests in Children Younger than Age 3 Years

Test | Study | Sensitivity* | Specificity* | Prevalence
MTI Photoscreener | Tong et al., 1998 ^29^ | 37% – 88% | 40% – 88% | 74%
| Cooper et al., 1999 ^31^ | 56% | 79% | 60%
| Cooper et al., 1999 ^31^ | 79% | 86% | 60%
| Tong et al., 2000 ^30^ | 65% | 87% | 74%
Visiscreen 100 | Cogen and Ottemiller, 1992 ^26^ | 65% | 87% | 12%

*No single screener achieved both sensitivity and specificity of greater than 70%.

The second study of the MTI photoscreener™ evaluated 105 children between 12 and 44 months old (no average age given) in an ophthalmology clinic.^31^ Two readers interpreted the photographs. In a population with 60% prevalence of visual impairment, the sensitivity and specificity was 56% and 79% by one reader and 61% and 86% by the other reader.

The third study of the MTI™ photoscreener evaluated 392 children, with an overall average age of 22 months (80% less than 36 months, 20% between 36 and 47 months old).^30^ Of these children, 74%had a visual impairment. Each photograph was evaluated by 1 of 2 readers familiar with photoscreening. The overall sensitivity was 65% and the specificity was 87%. Condition-specific sensitivities include 20% for cataract, 33% for refractive error, and 55% for strabismus.

One study evaluated the performance of the Visiscreen 100 in 113 children between 6 months and 6 years of age.^26^ No average age was provided. The prevalence of visual impairment in the study population was 12%. Overall sensitivity and specificity were 85% and 94%. No condition-specific sensitivities were provided.

Accuracy of Screening Tests in Children Aged 3 to 5 Years. One study of photoscreening and two studies of traditional vision screening that met the inclusion criteria addressed screening children 3 years of age and older (Table 5). The study of photoscreening evaluated 57 patients in an ophthalmology clinic with the Visiscreen 100 as interpreted by experts in photoscreening.^27^ The age ranged from 3 months to 8 years of age. The data presented suggest that the average age was greater than 4 years of age. Of these subjects, 12% had a visual disorder. Overall, the sensitivity was 91%; specificity, was 74%. Condition-specific sensitivities include 100% for cataracts and 93% for strabismus.

Table 5 Accuracy of Screening Tests in Children Aged 3 to 5 Years

Test | Study | Sensitivity | Specificity | Prevalence
Visiscreen 100 | Morgan and Johnson, 1987 ^27^ | 91% | 74% | 12%
Snellen E and Titmus stereotest or Stycar Graded balls | Kennedy et al., 1995 ^25^ | 33% | 97% | 9% – 12.5%
Cambridge Crowding Cards and Hirschberg test | Robinson et al., 1999 ^32^ | 62% | 76% | Not reported
Cambridge Crowding Cards and Stereofly | Robinson et al., 1999 ^32^ | 60% | 80% | Not reported
Cambridge Crowding Cards, Hirschberg test, and Stereofly | Robinson et al., 1999 ^32^ | 84% | 65% | Not reported

The first study of traditional vision screening evaluated 1,245 kindergarteners with the Snellen E test and the Titmus Stereotest.^25^ Children who were unable to perform the Snellen E test were evaluated with Stycar Graded balls. All children who failed these tests or failed an experimental photoscreener that was also being evaluated were referred for diagnostic evaluation. An additional 20% of the kindergarteners were also referred. Within this subpopulation, the overall sensitivity was 33% and the specificity was 97%. When these numbers are applied to the original population, the estimated sensitivity is 9% to 12.5% and the specificity is 99%. Within the subpopulation, condition-specific sensitivities include 33% for refractive error, 33% for strabismus, and 50% for combined refractive error and strabismus.

The other study of traditional vision screening evaluated a total of 3,434 kindergarteners over 3 years of age.^32^ Public health nurses administered the screening. In the first year, the children were screened by the Cambridge Crowding Cards, which include the letters “A,” “H,” “O,” “T,” “U,” “V,” and “X” (Haag Streit UK, London, England), and the Hirschberg test. During the second year, a test of stereoacuity, the Stereofly (Titmus Optical Co., Petersburg, Va.) was added. During the third year, the Hirschberg test was dropped. All children who failed were referred. For each child who was referred, another child, usually the next in line, was referred. The overall sensitivity, scaled to the total population, ranged from 60% to 71%, and the specificity ranged from 70% to 80%. During the second year of the study, when both the Hirschberg test and the stereoacuity test were used, the overall sensitivity was the highest (84%) and the specificity the lowest (65%). The sensitivity and specificity were similar in the first year when the stereoacuity test was not used (sensitivity 62%, specificity 76%) to the third year, when the Hirschberg test was not used (sensitivity 60%, specificity 80%). Among those in the referred group, the condition-specific sensitivities were 78% to 100% for strabismus and 92% to 100% for amblyopia.

## Key Questions 3 and 4: Effectiveness of Treatment

Primary Prevention of Amblyopia. — Early treatment of those conditions associated with amblyopia may prevent the development of amblyopia. However, few data are available regarding the effectiveness of primary prevention.

Strabismus. One study evaluated surgical treatment for strabismus in infants. Among 129 children treated by 2 years of age, 36.4% had normal stereopsis by 5 to 9 years of age.^33^ The most important factor in the outcome of treatment was the duration of the strabismus before surgical correction.

Refractive error. One study evaluated whether early treatment of hyperopia would prevent the development of strabismus.^34^ A community wide screening program identified 371 6-month-old children with hyperopia. These children were randomly allocated to spectacle treatment or no treatment. At 3.5 years, early treatment did not affect the development of strabismus (26% in untreated group, 31% in treated group). Although the study suggests that the final visual acuity in the worse eye was significantly better in those who were compliant with therapy (97% at least 20/30 in the treated versus 87% in the untreated group) no information is provided about whether this final acuity measure was corrected or uncorrected.

Cataracts. One study of cataracts included 25 subjects who had been treated for a cataract before 1 year of age.^35^ Of these children, 20% had achieved at least 20/40 vision by 5 years of age, but only those children who had had undergone surgery by 17 weeks of age experienced improvement in visual acuity.

Treatment of Amblyopia. — We found no trials comparing treatment to no treatment for amblyopia. Although such a study has been called for based on the British NHS report,^6^ many consider such a trial to be unethical.^36^ Indirect evidence of the effectiveness of treatment comes from cross-sectional studies comparing the prevalence of visual impairment in those who have been screened compared to those who have not been screened and from cohort studies of those who have been diagnosed with visual impairment.

Natural history of untreated amblyopia. One year after evaluating the prevalence of visual impairment among four- to six-year-olds residing in inner-city Baltimore,^19^ a follow-up study found that only 30% of children had received evaluation or completed treatment by an eye care specialist.^20^ Changes in the children with amblyopia who did not receive appropriate treatment over that year provide information about the natural history of untreated amblyopia. Overall, 15 children were found to be amblyopic at both screenings and failed to comply with therapy.^34^ Of these children, one (who wore glasses sporadically) had slight improvement in the amblyopic eye; four had deterioration in vision. These data suggest that amblyopia is unlikely to improve without therapy.

Prevalence rates of amblyopia in screened and unscreened populations. Sweden has an aggressive vision screening program, with repeat screening beginning with objective measures in infancy and extending to formal measures through 10 years of age. A retrospective cohort study found that by 10 years of age, the prevalence of amblyopia is 0.03%.^21^ This rate, which is much lower than the 3% rate found in the other prevalence studies, suggests that screening may reduce amblyopia. Similarly, a study in Israel found that the prevalence of amblyopia in 8-year-old children who received screening, including retinsoscopy, between 1 and 2.5 years of age was 1%, compared to 2.6% in an unscreened population.^37^

Outcomes of those Treated for Amblyopia. Evidence of the effectiveness of treatment for children with amblyopia comes from retrospective and prospective cohort studies. We considered improvement to be achievement of at least 20/40 in the amblyopic eye or clear evidence in another measurement that the eye had improved. Of the prospective studies in this review, between 41% and 96% of persons with amblyopia had improved visual acuity after treatment.^38^–^41^ These studies had between 25 and 255 subjects (mean, 112). Of the retrospective studies, between 40% and 95% of those with amblyopia achieved better visual acuity.^42^–^50^ These studies had between 51 and 961 subjects (mean, 280).

These cohort studies are not directly comparable. The types of visual impairment treated, the treatment type, treatment duration, individual compliance with therapy, and length of follow-up all varied among the studies; this heterogeneity precluded meta-analysis. In general, however, treatment does seem to be at least partially successful.

Two studies of treatment for amblyopia found that successful outcome depended on earlier treatment.^41,^ ^48^ The larger of these studies, a retrospective analysis of 407 children with strabismic amblyopia, demonstrated that treatment efficacy is highest for children younger than 3 years of age.^48^ Furthermore, treatment efficacy steadily decreased after 3 years of age; by 12 years of age, treatment was ineffective.

The stability of the improvement for those treated with amblyopia is unclear. None of the studies included in this review followed patients into adulthood.

Treatment of Refractive Errors Not Associated with Amblyopia. — Treatment of refractive errors not associated with amblyopia is by spectacle correction. In 1 retrospective cohort study, 98% of preschool children corrected to normal vision.^45^

## Key Question 5: Clinical Consequences

Few data are available regarding the consequences of visual impairment that is untreated before 5 years of age. The literature searches yielded 1 study on the association between visual impairment and learning or intelligence.^51^ In this study of 10-year-old children from England, subjects with amblyopia had a statistically significant lower score on the British Ability Scales than children with normal vision (98.4 versus 100; standard deviation 15). The importance of this finding is unclear, because the absolute difference was small. Furthermore, a cross-sectional study cannot establish causality. However, a small shift in ability to learn or intelligence may have an important impact on society.

We were interested in the relationship between amblyopia and quality of life. Because amblyopia untreated in the early years may be permanent, we searched for data regarding the effect of amblyopia on persons of all ages.

One study explored the relationship between amblyopia and quality of life.^52^ This survey was administered to 45 adults with amblyopia but without strabismus. Of the respondents, nearly 50% reported that amblyopia interfered with schooling and work and nearly 75% reported that amblyopia affected their self-image. These subjects were recruited in an academic ophthalmologic practice, raising questions about generalizability. Furthermore, this study had a response rate of 56%, which raises concern about selection bias.

Amblyopia may be a risk factor for future total blindness. A retrospective study from Finland found 23 cases in which people with amblyopia subsequently become totally blind.^53^ The authors reviewed the prevalence of amblyopia and the population from which these cases arose to determine the risk of loss of vision in the non-amblyopic eye. The risk of vision loss (1.75 ± 0.30 cases per 1,000 persons) among those with amblyopia was found to be greater than among the general population (0.66 cases per 1,000 persons). Accidental trauma was associated with more than half of the cases of total vision loss in those with amblyopia. This study may be biased by the assumptions regarding prevalence and population size.

Although certain jobs require normal stereoacuity (depth perception), such as piloting aircraft, we were unable to find any study detailing the relationship between amblyopia and job performance. However, the requirement for the absence of amblyopia for a given occupation does not mean that there is a basis for such a requirement. The ability to perform jobs that require near-work, however, is more likely to be affected by amblyopia.

Little is known about the consequences of untreated visual impairments in young children. Furthermore, few data are available regarding the long-term burden of suffering caused by amblyopia.

## Key Questions 6, 7, and 8: Harms of Screening and Treatment

No article that met the criteria for inclusion in this review detailed any harm directly resulting from screening or mentioned any harm from an eye examination, such as a side effect from dilating the eyes. No data were found regarding the harms of false-positive screening.

One study of the treatment of amblyopia found that visual acuity of the non-amblyopic eye can decrease on average to 20/182 as a result of patching.^48^ However, this loss of visual acuity was not permanent and resolved weeks after therapy was ended.

A potential harm of early treatment visual impairment is interference with the normal development of the eye. Because the development of the eye, or emmetropization, partially depends upon the quality of image that an eye receives, some experts have suggested that interfering with this image, even by correction, may impair normal development.^8^ An analysis of the study of early treatment of hyperopia found that emmetropization did not occur in 42% of treated children compared to 31% of those not given spectacles.^54^ Although the precise course of normal emmetropization is unclear, these data suggest that early intervention may be harmful.