# Methods

## Literature Search Strategy

To identify articles relevant to the questions of screening and treatment of visual impairment, we searched the MEDLINE database in numerous iterations from 1966 to the present. Two analytic frameworks (Figures 1 and 2) guided the literature searches. Analytic Framework A (Figure 1) depicts screening asymptomatic children for amblyopia or conditions associated with amblyopia. Analytic Framework B (Figure 2) depicts screening asymptomatic children for refractive error not associated with amblyopia. In each analytic framework, the overarching issue on which we sought evidence is the relationship between screening asymptomatic children for visual impairment and health outcomes.

Figure 1. Vision Impairment Screening: Analytic Framework A

Figure 2. Vision Impairment Screening: Analytic Framework B

Issues of screening and treatment are likely to be different for very young children and older children. For this reason, we paid special attention to differences between children less than 3 years of age and children between 3 and 5 years of age. Based on the analytic frameworks and the concern about differences in the age groups, we developed the following 8 key questions, also noted on the analytic frameworks:

1 What is the prevalence of visual impairment in children through 5 years of age?
2 Do reliable, accurate, and feasible screening tests exist that can be used to detect visual disorders in children less than 3 years of age or in children between the ages of 3 and 5 years? These visual disorders include amblyopia, strabismus, refractive errors associated with amblyopia, other more rare conditions associated with amblyopia such as cataracts or ptosis, and refractive error not associated with amblyopia.
3 Do detection and treatment of conditions associated with amblyopia before amblyopia has developed lead to better treatment outcomes (primary prevention)?
4 Under what conditions is the treatment of amblyopia successful?
5 Under what conditions is the treatment of refractive errors not associated with amblyopia successful?
6 Does improving vision result in improved health outcomes?
7 What are the adverse effects of screening?
8 What are the adverse effects of treatment?

We established inclusion and exclusion criteria prospectively for all searches (Table 1). We supplemented these MEDLINE searches by reviewing the bibliographies of included articles and other systematic reviews, meta-analyses, and evidence-based practice guidelines that addressed screening for visual impairment. Table 2 documents the results of the literature searches for each of the 8 key questions; Table 3 summarizes the outcomes of all items identified from review of abstracts to inclusion in evidence tables.

Table 1 Vision Impairment: General Inclusion and Exclusion Criteria

Category | Inclusion | Exclusion
Databases | MEDLINE | Other databases
Languages | English only | Other languages
Populations | Humans only | Animal studies
Study design | All | No editorials, letters to editors

Table 2 Vision Impairment: Search Strategy Results

Search Strategy for Key Question 1
1 | Explode vision disorders | 30,455
2 | Explode prevalence | 41,870
3 | 2 and 3 | 413
4 | Limit 4 to (human and English language and (newborn infant < birth to 1 month > or infant < 1 to 23 months > or preschool child < 2 to 5 years >)) | 128
Search Strategy for Key Question 2
1 | Explode vision tests | 14,570
2 | Limit 1 to (human and English language and (newborn infant < birth to 1 month > or infant < 1 to 23 months > or preschool child < 2 to 5 years >)) | 1439
3 | Explode randomized controlled trials, or explode single-blind method, or explode double-blind method, or explode random allocation | 105,639
4 | 2 and 3 | 48
Search Strategy for Key Questions 3 and 4
1 | Explode amblyopia | 3,252
2 | Treatment outcome | 81,783
3 | 1 and 2 | 69
4 | Limit 3 to (human and English language) | 56
Search Strategy for Key Question 5
1 | Explode vision disorders | 30,455
2 | Explode amblyopia | 3252
3 | 1 not 2 | 27,203
4 | Explode treatment outcome | 86819
5 | 3 and 4 | 268
6 | Limit 5 to (human and English language and (newborn infant < birth to 1 month > or infant < 1 to 23 months > or preschool child < 2 to 5 years >)) | 36
8 | Explode refractive errors | 11,755
9 | 4 and 8 | 660
10 | Limit 9 to (human and English language and (newborn infant < birth to 1 month > or infant < 1 to 23 months > or preschool child < 2 to 5 years >)) | 38
11 | 10 not 6 | 36
Search Strategies for Key Question 6
1 | Explode amblyopia | 3,252
2 | Blindness | 9,578
3 | 1 and 2 | 73
4 | Limit 3 to (human and English language) | 33
1 | Explode risk, or explode risk factors, or explode risk-taking | 219,156
2 | Explode amblyopia, or explode vision, monocular, or “monocular blindness” | 4,335
3 | 1 and 2 | 54
4 | Not in the “Wound and injury” section | 52
5 | Limit 4 to (human and English language) | 39
1 | Explode amblyopia, or explode vision disorders | 30,455
2 | Explode learning | 116,708
3 | Explode education | 269,574
4 | 2 or 3 | 378,968
5 | 1 and 4 | 1,418
6 | Limit 6 to (human and English language and age 0–5 years) | 211
1 | Explode amblyopia | 3,252
2 | Explode vision, monocular, or “monocular blindness” | 1,127
3 | 1 or 2 | 4,335
4 | Explode “Wounds and injuries” | 339,109
5 | 3 and 4 | 100
6 | Limit 5 to (human and English language) | 72
Search Strategy for Key Question 7
1 | Explode amblyopia | 3,252
2 | Explode mass screening/ae [Adverse Effects] | 144
3 | 1 and 2 | 0
4 | Explode vision disorders or “vision impairment” | 30,508
5 | 2 and 4 | 0
6 | Explode vision | 83,307
7 | 2 and 6 | 0
Search Strategy for Key Question 8
1 | Explode anxiety | 22,603
2 | Explode emotions, or explode shame, or “embarrassment” | 65,764
3 | 1 or 2 | 65,764
4 | Explode amblyopia | 3,252
5 | 3 and 4 | 5
6 | Explode eyeglasses | 3,539
7 | 2 and 6 | 85
8 | 5 or 7 | 87
9 | Limit 8 to (Human and English Language) | 59

Table 3 Summary Results from Literature Searches and Reviews

Search and Review Results | KQ1 | KQ2 | KQ3 and KQ4 | KQ5 | KQ6 | KQ7 | KQ8
Number of Abstracts
From literature search | 128 | 48 | 56 | 36 | 355 | 0 | 59
From supplemental search | 6 | 15 | 16 | 1 | 1 | 0 | 1
Reviewed | 134 | 63 | 75 | 37 | 356 | 0 | 60
Excluded at abstract review phase | 118 | 39 | 31 | 27 | 345 | 0 | 55
Included for full article review | 16 | 24 | 44 | 10 | 11 | 0 | 5
Number of Articles
Excluded after full review | 10 | 17 | 25 | 9 | 8 | 0 | 3
Included in Evidence Summary | 6 | 7 | 6,13 | 1 | 3 | 0 | 2
Included in Evidence Tables | 6 | 7 | 3,13 | 1 | 3 | 0 | 2

## Literature Reviewed

One reader reviewed each title and abstract of the articles identified by the literature searches and excluded those that did not meet eligibility criteria. EPC staff then entered study design and outcomes data from the articles that had met inclusion criteria into seven evidence tables, organized by key question; we identified no literature about harms of screening. We assigned quality grades according to criteria established by the USPSTF Methods Work Group.^17^