# References

1 Clinical management guidelines for obstetrician-gynecologists. Number 30, September 2001. Obstet Gynecol. 2001;98:525-538. [pmid: 11547793].
2 Magee MS, Walden CE, Benedetti TJ, Knopp RH. Influence of diagnostic criteria on the incidence of gestational diabetes and perinatal morbidity. JAMA. 1993;269:609-615. [pmid: 8421365].
3 Solomon CG, Willet WC, Carey VJ, et al. A prospective study of pregravid determinants of gestational diabetes mellitus. JAMA. 1997;278:1078-1083. [pmid: 9315766].
4 Moses RG, Moses J, Davis WS. Gestational diabetes: do lean young Caucasian women need to be tested?. Diabetes Care. 1998;21:1803-1806. [pmid: 9802724].
5 Lavin, JP, Barden, TP, and Miodovnik, M Clinical experience with a screening program for gestational diabetes Am J Obstet Gynecol. 1981 141(5):491 494 7294074
6 Marquette GP, Klein VR, Niebyl JR. Efficacy of screening for gestational diabetes. Am J Perinatol. 1985;2:7-9. [pmid: 3921038].
7 Lemen PM, Wington TR, Miller-McCarthy AJ, Cruikshank DW Screening for gestational diabetes mellitus in adolescent pregnancies Am J Obstet Gynocol. 1998 178(6):1251 6
8 Southwick RD, Wigton TR. Screening for gestational diabetes mellitus in adolescent Hispanic Americans. J Reprod Med. 2000;45:31-34. [pmid: 10664944].
9 Harlass FE, Brady K, Read JA. Reproducibility of the oral glucose tolerance test in pregnancy. Am J Obstet Gynecol. 1991;164:564-568. [pmid: 1992702].
10 Massion C, O'Connor PJ, Gorab R, Crabtree BF, Nakamura RM, Coulehan JL. Screening for gestational diabetes in a high-risk population. J Fam Pract. 1987;25:568-575.
11 Weiner CP, Fraser MM, Burns JM, Schnoor D, Herrig J, Whitaker LA. Cost efficacy of routine screening for diabetes in pregnancy: 1-h versus 2-h specimen. Diabetes Care. 1986;9:255-259. [pmid: 3089747].
12 Hunter DJS. Diabetes in Pregnancy. Effective Care in Pregnancy and Childbirth. Toronto: Oxford University Press. 1989:578-593.
13 Canadian Task Force on the Periodic Health Examination. Screening for gestational diabetes mellitus. Can Med Assoc J. 1992;147:435-443. [pmid: 1306050].
14 US Preventive Services Task Force. Screening for gestational diabetes. Guide to Clinical Preventive Services, 2nd Ed. Baltimore: Williams and Wilkins. 1996:193-208. [pmcid: 157938].
15 Hoffman L, Nolan C, Wilson JD, Oats JJ, Simmons D. Gestational diabetes mellitus--management guidelines. The Australasian Diabetes in Pregnancy Society. Med J Austral. 1998;169:93-97. [pmid: 9700346].
16 Oats JJ. Fourth International Workshop-Conference on Gestational Diabetes Mellitus. Overview and commentary on first session. Diabetes Care. 1998;21:B58-B59. [pmid: 9704228].
17 American Diabetes Association. Gestational Diabetes Mellitus. Diabetes Care. 1999;22.
18 Wilkins-Haug L, Horton JA, Cruess DF, Frigoletto FD. Antepartum screening in the office-based practice: findings from the collaborative ambulatory research network. Obstet Gynecol. 1996;88:483-489. [pmid: 8841204].
19 American College of Obstetricians and Gynecologists. Management of diabetes mellitus in pregnancy. ACOG Technical Bulletin No. 200. Washington, DC: AGOG; December 1994.
20 Harris RP, Helfand M, Woolf SH, et al Current Methods of the US Preventive Services Task Force: A Review of the Process Am J Prev Med. 2001 2(3S):21 35
21 Griffin ME, Coffey M, Johnson H, et al. Universal vs. risk factor-based screening for gestational diabetes mellitus: detection rates, gestation at diagnosis and outcome. Diabet Med. 2000;17:26-32. [pmid: 10691156].
22 Santini DL, Ales KL. The impact of universal screening for gestational glucose intolerance on outcome of pregnancy. Surg Gynecol Obstet. 1990;170:427-436. [pmid: 2326724].
23 Beischer NA, Wein P, Sheedy MT, Steffen B. Identification and treatment of women with hyperglycaemia diagnosed during pregnancy can significantly reduce perinatal mortality rates. Aust NZ J Obstet Gynaecol. 1996;36:239-247.
24 Gabbe SG, Mestman JH, Freeman RK, et al. Management and outcome of Class A diabetes mellitus. Am J Obstet Gynecol. 1977;127:465-469. [pmid: 836643].
25 Santini DL, Ales KL. The impact of universal screening for gestational glucose intolerance on outcome of pregnancy. Surg Gynecol Obstet. 1990;170:427-436. [pmid: 2326724].
26 Sermer M, Naylor CD, Farine D, et al. The Toronto Tri-Hospital Gestational Diabetes Project. A preliminary review. Diabetes Care. 1998;21:B33-B42. [pmid: 9704225].
27 Wen SW, Kramoer M, Joseph KS, Levitt C, Marcoux S, Liston R. Impact of prenatal glucose screening on the diagnosis of gestational diabetes and on pregnancy outcomes. Am J Epidem. 2000;152:1009-1014. discussion 1015-106.
28 Sermer M, Naylor DC, Gare DJ, et al. Impact of increasing carbohydrate intolerance on maternal-fetal outcomes in 3637 women without gestational diabetes: The Toronto Tri-Hospital Gestational Diabetes Project. Am J Obstet Gynecol. 1995;173:146-156. [pmid: 7631672].
29 Sacks DA, Greenspoon JS, Abu-Fadil S, Henry HM, Wolde-Tsadik G, Yao JFF. Toward universal criteria for gestational diabetes: the 75-gram glucose tolerance test in pregnancy. Am J Obstet Gynecol. 1995;172:607-614. [pmid: 7856693].
30 Langer O, Levy J, Brustman L, Anyaegbunam A, Merkatz R, Divon M. Glycemic control in gestational diabetes mellitus - how tight is tight enough: small for gestational age vs. large for gestational age?. Am J Obstet Gynecol. 1989;161:646-653. [pmid: 2782347].
31 Naylor CD. Diagnosing gestational diabetes: is the gold standard valid?. Diabetes Care. 1989;12:565-572. [pmid: 2673696].
32 O'Sullivan JB, Gellis SS, Dandrow RV, Tenney BO The potential diabetic and her treatment in pregnancy Obstetrics & Gynecology. 1966 27(5):683 689 5936737
33 Pettitt DJ, Knowler WC, Baird HR, Bennett PH. Gestational diabetes: infant and maternal complications of pregnancy in relation to third-trimester glucose tolerance in Pima Indians. Diabetes Care. 1980;3:458-464. [pmid: 7389563].
34 Adams KM, Li H, Nelson RL, Ogburn PL Jr, Danilenko-Dixon DR. Sequelae of unrecognized gestational diabetes. Am J Obstet Gynecol. 1998;178:1321-1332. [pmid: 9662318].
35 Naylor CD, Sermer M, Chen E, Sykora K. Cesarean delivery in relation to birth weight and gestational glucose tolerance: pathophysiology or practice style? Toronto Tri-Hospital Gestational Diabetes Investigators. JAMA. 1996;275:1165-1170. [pmid: 8609683].
36 Garner P, Okun N, Keely E, et al. A randomized controlled trial of strict glycemic control and tertiary level obstetric care versus routine obstetric care in the management of gestational diabetes: a pilot study. Am J Obstet Gynecol. 1997;177:190-195. [pmid: 9240606].
37 Lu G, Rouse D, Dubard M, Cliver S. The impact of lower threshold values for the detection of gestational diabetes mellitus. Obstet Gynecol. 2000;95.
38 Li DFH, Wong VCW, O'Hoy KMKY, Ma HK. Is treatment needed for mild impairment of glucose in pregnancy? A randomized controlled trial. Br J Obstet Gynaecol. 1987;94:851-854. [pmid: 3311138].
39 Mondalou HD, Dorchester WL, Thorosian A, Freeman RK. Macrosomia - maternal, fetal, and neonatal implications. Obstet Gynecol. 1980;55:420-424. [pmid: 7366896].
40 Lu GC, Rouse DJ, Dubard M, Cliver S, Kimberlin D, Hauth JC. The effect of the increasing prevalence of maternal obesity on perinatal morbidity. Am J Obstet Gynecol. 2001;185:845-849. [pmid: 11641663].
41 Ventura SJ, Martin JA, Curtin SC, Mathews TJ, Park MM. Births: final data for 1998. Natl Vital Stat Rep. 2000;48:1-100.
42 Xiong X, Saunders LD, Wang FL, Demianczuk NN. Gestational diabetes mellitus: prevalence, risk factors, maternal and infant outcomes. Int J Gynaecol Obstet. 2001;75:221-228. [pmid: 11728481].
43 Svare JA, Hansen BB, Molsted-Pedersen L. Perinatal complications in women with gestational diabetes mellitus. Acta Obstet Gynecol Scand. 2001;80:899-904. [pmid: 11580734].
44 Gross TL, Sokol RJ, Williams T, Thompson K. Shoulder dystocia: a fetal-physician risk. Am J Obstet Gynecol. 1987;156:1408-1418. [pmid: 3591856].
45 McFarland LV, Raskin M, Daling JR, Benedetti TJ. Erb/Duchenne's palsy: a consequence of fetal macrosomia and method of delivery. Obstet Gynecol. 1986;68:784-788. [pmid: 3785790].
46 Sandmire HF, O'Halloin TJ. Shoulder dystocia: its incidence and associated risk factors. Int J Gynaecol Obstet. 1988;26:65-73. [pmid: 2892741].
47 Okun N, Verma A, Mitchell BF, Flowerdew G. Relative importance of maternal constitutional factors and glucose intolerance of pregnancy in the development of newborn macrosomia. J Matern Fetal Med. 1997;6:285-290. [pmid: 9360188].
48 Lucas MJ, Lowe TW, Bowe L, McIntire DD. Class A1 gestational diabetes: a meaningful diagnosis?. Obstet Gynecol. 1993;82:260-265. [pmid: 8336875].
49 Spellacy WN, Miller S, Winegar A, Peterson PQ. Macrosomia - maternal characteristics and infant complications. Obstet Gynecol. 1985;66:158-161. [pmid: 4022478].
50 Hod M, Bar J, Peled Y, et al Antepartum management protocol. Timing and mode of delivery in gestational diabetes Diabetes Care. 1998 21Suppl 2:B113 B117 9704237
51 Lipscomb KR, Gregory K, Shaw K. The outcome of macrosomic infants weighing at least 4500 grams: Los Angeles County + University of Southern California experience. Obstet Gynecol. 1995;85:558-564. [pmid: 7898833].
52 Berard J, Dufour P, Vinatier D, et al. Fetal macrosomia: risk factors and outcome. A study of the outcome concerning 100 cases >4500 g. Eur J Obstet Gynecol Reprod Biol. 1998;77:51-59. [pmid: 9550201].
53 Bryant DR, Leonardi MR, Landwehr JB, Bottoms SF. Limited usefulness of fetal weight in predicting neonatal brachial plexus injury. Am J Obstet Gynecol. 1998;179:686-689. [pmid: 9757972].
54 Acker DB, Gregory WM, Sachs BP, Friedman EA. Risk factors for Erb-Duchenne palsy. Obstet Gynecol. 1988;71:389-392. [pmid: 3347425].
55 Ecker JL, Greenburg JA, Norwitz ER, Nadel AS, Repke JT. Birth weight as a predictor of brachial plexus injury. Obstet Gynecol. 1997;89:643-647. [pmid: 9166293].
56 Perlow JH, Wigton T, Hart J, Strassner HT, Nageotte MP, Wolk BM. Birth trauma. A five-year review of incidence and associated perinatal factors. J Reprod Med. 1996;41:754-760. [pmid: 8913978].
57 Gordon M, Rich H, Deutschberger J, Green M. The immediate and long-term outcome of obstetric birth trauma. I. Brachial plexus paralysis. Am J Obstet Gynecol. 1973;117:51-56. [pmid: 4722378].
58 Kolderup LB, Laros RK Jr, Musci TJ. Incidence of persistent birth injury in macrosomic infants: association with mode of delivery. Am J Obstet Gynecol. 1997;177:37-41. [pmid: 9240580].
59 Blickstein I, Ben-Arie A, Hagay ZJ. Antepartum risks of shoulder dystocia and brachial plexus injury for infants weighing 4,200 grams or more. Gynecol Obstet Invest. 1998;45:77-80. [pmid: 9517796].
60 Nesbitt TS, Gilbert WM, Herrchen B. Shoulder dystocia and associated risk factors with macrosomic infants born in California. Am J Obstet Gynecol. 1998;179:476-480. [pmid: 9731856].
61 Bahar AM. Risk factors and fetal outcome in cases of shoulder dystocia compared with normal deliveries of a similar birthweight. Brit J Obstet Gynaecol. 1996;103:868-872. [pmid: 8813305].
62 McFarland MB, Trylovich CG, Langer O. Anthropometric differences in macrosomic infants in diabetic and nondiabetic mothers. J Matern Fetal Med. 1998;7:292-295. [pmid: 9848695].
63 Langer O, Rodriguez DA, Xenakis EM, McFarland MB, Berkus MD, Arrendondo F. Intensified versus conventional management of gestational diabetes. Am J Obstet Gynecol. 1994;170:1036-1046. discussion 1046-1047. [pmid: 8166187].
64 Casey BM, Lucas MJ, Mcintire DD, Leveno KJ. Pregnancy outcomes in women with gestational diabetes compared with the general obstetric population. Obstet Gynecol. 1997;90:869-873. [pmid: 9397092].
65 Kjos SL, Schaefer-Graf U, Sardesi S, et al. A randomized controlled trial using glycemic plus fetal ultrasound parameters versus glycemic parameters to determine insulin therapy in gestational diabetes with fasting hyperglycemia. Diabetes Care. 2001;24:1904-10. [pmid: 11679455].
66 Morrison JC, Sanders JR, Magann EF, Wiser WL. The diagnosis and management of dystocia of the shoulder. Surg Gynecol Obstet. 1992;175:515-522. [pmid: 1448731].
67 Hardy AE. Birth injuries of the brachial plexus: incidence and prognosis. J Bone Joint Surg Br. 1981;63-B:98-101. [pmid: 7204481].
68 Oppenheim WL, Davis A, Growdon WA, Dorey FJ, Davlin LB. Clavicle fractures in the newborn. Clin Orthop. 1990;250:176-180. [pmid: 2293927].
69 Chez RA, Carlan S, Greenberg SL, Spellacy WN. Fractured clavicle is an unavoidable event. Am J Obstet Gynecol. 1994;171:797-798. [pmid: 8092231].
70 Hod M, Rabinerson D, Peled Y. Gestational diabetes mellitus: is it a clinical entity?. Diabetes Reviews. 1995;3:602-613.
71 Ogata E. Perinatal morbidity in offspring of diabetic mothers. Siabetes Reviews. 1995;3:652-657.
72 Langer O, Conway D, Berkus M, Xenakis E, Gonzales O. A comparison of glyburide and insulin on women with gestational diabetes mellitus. NEJM. 2000;343:1134-1138. [pmid: 11036118].
73 Langer O. Management of gestational diabetes. Clin Obstet Gynecol. 2000;43:106-115. [pmid: 10694993].
74 Langer O. Maternal glycemic criteria for insulin therapy in gestational diabetes mellitus. Diabetes Care. 1998;21:B91-B98. [pmid: 9704234].
75 Silverman B, Metzger B, Cho N, Loeb C. Impaired glucose tolerance in adolescent offspring of diabetic mothers. Relationship to fetal hyperinsulinism. Diabetes Care. 1995;18:611-617. [pmid: 8585997].
76 Pettitt DJ, Bennett PH, Knowler WC, Baird HR, Aleck KA. Gestational diabetes mellitus and impaired glucose tolerance during pregnancy. Long-term effects on obesity and glucose tolerance in the offspring. Diabetes. 1985;34:119-122. [pmid: 3996763].
77 Pettitt D. J., Bennett P. H., Saad M. F., Charles M. A., Nelson R. G., Knowler W. C Abnormal glucose tolerance during pregnancy in Pima Indian women. Long-term effects on offspring Diabetes. 1991 40Suppl :126 130 1748241
78 Plagemann A, Harder T, Kohlhoff R, Rohde W, Dorner G. Glucose tolerance and insulin secretion in children of mothers with pregestational IDDM or gestational diabetes. Diabetologia. 1997;40:1094-1100. [pmid: 9300247].
79 Beischer NA, Wein P, Sheedy MT, Werther GA, Gold H. Maternal glucose tolerance and obstetric complications in pregnancies in which the offspring developed type I diabetes. Diabetes Care. 1994;17:832-834. [pmid: 7956626].
80 Vohr BR, Lipsitt LP, Oh W. Somatic growth of children of diabetic mothers with reference to birth size. J Pediatr. 1980;97:196-9. [pmid: 7400885].
81 Silverman B. L., Rizzo T, Green O. C., et al. Long-term prospective evaluation of offspring of diabetic mothers. Diabetes. 1991;40:121-125. [pmid: 1748240].
82 Persson B, Gentz J, Moller E. Follow-up of children of insulin dependent (type I) and gestational diabetic mothers. Growth pattern, glucose tolerance, insulin response, and HLA types. Acta Paediatr Scand. 1984;73:778-784. [pmid: 6395625].
83 Pettitt DJ, Baird HR, Aleck KA, Bennett PH, Knowler WC. Excessive obesity in offspring of Pima Indian women with diabetes during pregnancy. N Engl J Med. 1983;308:242-5. [pmid: 6848933].
84 Whitaker RC, Pepe MS, Seidel KD, Wright JA, Knopp RH. Gestational diabetes and the risk of offspring obesity. Pediatrics. 1998;101.
85 Vohr BR, McGarvey ST, Tucker R. Effects of maternal gestational diabetes on offspring adiposity at 4-7 years of age. Diabetes Care. 1999;22:1284-1291. [pmid: 10480772].
86 Silverman BL, Rizzo TA, Cho NH, Metzger BE. Long-term effects of the intrauterine environment. The Northwestern University Diabetes in Pregnancy Center. Diabetes Care. 1998;21:B142-B149. [pmid: 9704242].
87 Rizzo TA, Silverman BL, Metzger BE, Cho NH. Behavioral adjustment in children of diabetic mothers. Acta Paediatr. 1997;86:969-74. [pmid: 9343277].
88 Ornoy A, Ratzon N, Greenbaum C, Wolf A, Dulitzky M School-age children born to diabetic mothers and to mothers with gestational diabetes exhibit a high rate of inattention and fine and gross motor impairment J Pediatr Endocrinol Metab. 2001 14Suppl 1:681 689 11393563
89 Rizzo TA, Dooley SL, Metzger BE, Cho NH, Ogata ES, Silverman BL. Prenatal and perinatal influences on long-term psychomotor development in offspring of diabetic mothers [see comments]. Am J Obstet Gynecol. 1995;173:1753-1758. [pmid: 8610757].
90 Menticoglou SM, Manning FA, Morrison I, Harman CR. Must macrosomic fetuses be delivered by cesarean section? A review of outcome for 786 babies greater than or equal to 4,500 grams. Aust N Z J Obstet Gynaecol. 1992;32:100-103. [pmid: 1520190].
91 Rouse DJ, Owen J. Prophylactic cesarean delivery for fetal macrosomia diagnosed by means of ultrasonography--A Faustian bargain?. Am J Obstet Gynecol. 1999;181:332-338. [pmid: 10454678].
92 Lazer S, Biale Y, Mazor M, Lewenthal H, Insler V. Complications associated with the macrosomic fetus. J Reprod Med. 1986;31:501-505. [pmid: 3735262].
93 el Madany AA, Jallad KB, Radi FA, el Hamdan H, O'deh HM. Shoulder dystocia: anticipation and outcome. Int J Gynaecol Obstet. 1990;34:7-12. [pmid: 1671025].
94 Joffe GM, Esterlitz JR, Levine RJ, et al. The relationship between abnormal glucose tolerance and hypertensive disorders of pregnancy in healthy nulliparous women. Calcium for Preeclampsia Prevention (CPEP) Study Group. Am J Obstet Gynecol. 1998;179:1032-1037. [pmid: 9790393].
95 Suhonen L, Teramo K. Hypertension and pre-eclampsia in women with gestational glucose intolerance. Acta Obstetricia Et Gynecologica Scandinavica. 1993;72:269-272. [pmid: 8389513].
96 Schaffir JA, Lockwood CJ, Lapinski R, Yoon L, Alvarez M. Incidence of pregnancy-induced hypertension among gestational diabetics. Am J Perinatol. 1995;12:252-254. [pmid: 7575828].
97 Jensen DM, Sorensen B, Feilberg-Jorgensen N, Westergaardt JG, Beck-Neilsen H. Maternal and perinatal outcomes in 143 Danish women with gestational diabetes mellitus and 143 controls with a similar risk profile. Diabet Med. 2000;17:281-286. [pmid: 10821294].
98 Roach VJ, Hin LY, Tam WH, Ng KB, Rogers MS. The incidence of pregnancy-induced hypertension among patients with carbohydrate intolerance. Hypertens Pregnancy. 2000;19:183-189. [pmid: 10877986].
99 Persson B, Hanson U Neonatal morbidities in gestational diabetes mellitus Diabetes Care. 1998 21Suppl 2:B79 B84 9704232
100 Lao TT, Tam KF. Gestational diabetes diagnosed in third trimester pregnancy and pregnancy outcome. Acta Obstet Gynecol Scand. 2001;80:1003-1008. [pmid: 11703196].
101 Sebire NJ, Jolly M, Harris JP, et al. Maternal obesity and pregnancy outcome: a study of 287 213 pregnancies in London. Int J Obes Relat Metab Disord. 2001;25:1175-1182. [pmid: 11477502].
102 Baeten JM, Bukusi EA, Lambe M. Pregnancy complications and outcomes among overweight and obese nulliparous women. Am J Public Health. 2001;91:436-440. [pmid: 11236410].
103 Naylor C.D., Sermer M, Chen E, Farine D. Selective screening for gestational diabetes mellitus. Toronto Tri-Hospital Gestational Diabetes Project Investigators. New Engl J Med. 1997;337:1591-1596. [pmid: 9371855].
104 Persson B, Strangenberg M, Hansson U, Norlander E. Gestational diabetes mellitus (GDM) comparative evaluation of two treatment regimens, diet versus insulin and diet. Diabetes. 1985;11:101-105. [pmid: 14461447].
105 Nachum Z, Ben-Shlomo I, Weiner E, Shalev E. Twice daily versus four times daily insulin dose regimens for diabetes in pregnancy: randomised controlled trial. BMJ. 1999;319:1223-1227. [pmid: 10550081]. [pmcid: 28269].
106 de Veciana M, Major CA, Morgan MA, et al. Postprandial versus preprandial blood glucose monitoring in women with gestational diabetes mellitus requiring insulin therapy. N Engl J Med. 1995;333:1237-1241. [pmid: 7565999].
107 O'Sullivan JB. Diabetes mellitus after GDM. Diabetes. 1991;40:131-135. [pmid: 1748242].
108 Wein P, Beischer NA, Sheedy MT. Studies of postnatal diabetes mellitus in women who had gestational diabetes. Part 2. Prevalence and predictors of diabetes mellitus after delivery. Aust NZ J Obstet Gynecol. 1997;37:420-423.
109 Kjos SL, Peters RK, Xiang A, Henry OA, Montoro M, Buchanan TA. Predicting future diabetes in Latino women with gestational diabetes. Utility of early postpartum glucose tolerance testing. Diabetes. 1995;44:586-591. [pmid: 7729620].
110 Henry OA, Beischer NA, Sheedy MT, Walstab JE. Gestational diabetes and follow-up among immigrant Vietnam-born women. Austral NZ J Obstet Gynaecol. 1993;33:109-114.
111 Henry OA, Beischer NA. Long-term implications of gestational diabetes for the mother. Baillieres Clin Obstet Gynaecol. 1991;5:461-483. [pmid: 1954723].
112 O'Sullivan JB, Mahan CM. Criteria for oral glucose tolerance test in pregnancy. Diabetes. 1964.
113 O'Sullivan JB. Gestational diabetes: factors influencing the rates of subsequent diabetes. In: Sutherland HW, Stowers JM, eds. Carbohydrate Metabolism in Pregnancy and the Newborn. Berlin, Germany: Springer Verlag. 1979:421-425.
114 Mestman JH, Anderson GV, Guadalupe V. Follow-up studies of 360 subjects with abnormal carbohydrate metabolism during pregnancy. Obstet Gynecol. 1972;39:421-425. [pmid: 5019316].
115 Persson B, Hanson U, Hartling SG, Binder C Follow-up of women with previous GDM. Insulin, C-peptide, and proinsulin responses to oral glucose load Diabetes. 1991 40Suppl 2:136 41:136-141 1748243
116 Damm P, Kuhl C, Bertelsen A, Molsted-Pedersen L. Predictive factors for the development of diabetes in women with previous gestational diabetes mellitus. Am J Obstet Gynecol. 1992;167:607-616. [pmid: 1530012].
117 Metzger BE, Cho NH, Roston SM, Radvany R. Prepregnancy weight and antepartum insulin secretion predict glucose tolerance five years after gestational diabetes mellitus. Diabetes Care. 1993;16:1598-1605. [pmid: 8299456].
118 Coustan DR, Carpenter MW, O'Sullivan PS, Carr SR. Gestational diabetes: predictors of subsequent disordered glucose metabolism. Am J Obstet Gynecol. 1993;168:1139-1144. discussion 1144-1145. [pmid: 8475959].
119 Manson JE, Rimm EB, Colditz GA, et al. Parity and incidence of non-insulin-dependent diabetes mellitus. Am J Med. 1992;93:13-18. [pmid: 1626567].
120 US. Preventive Services Task Force. Screening for diabetes. Guide to Clinical Preventive Services, 2nd Ed. Baltimore: Office of Disease Prevention and Health Promotion. 1996. [pmcid: 190016].
121 Metzger BE, Coustan DR. Summary and recommendations of the Fourth International Workshop-Conference pm gestational diabetes mellitus. Diabetes Care. 1998;21:B161-7. [pmid: 9704245].
122 National Diabetes Data Group. Classification and diagnosis of diabetes mellitus and other categories of glucose intolerance. Diabetes. 1979;28:1039-1057. [pmid: 510803].
123 Coustan DR. Making the diagnosis of gestational diabetes mellitus. Clinical Obstetrics & Gynecology. 2000;43:99-105. [pmid: 10694992].
124 Sacks DA, Salim AF, Greenspoon JS, et al. Do the current standards for glucose intolerance testing in pregnancy represent a valid conversion of O'Sullivan's original criteria?. Am J Obstet Gynecol. 1989;161:638-641. [pmid: 2782345].
125 Carpenter MW, Coustan DR. Criteria for screening tests for gestational diabetes. Am J Obstet Gynecol. 1982;144:768-773. [pmid: 7148898].
126 American Diabetes Association. Gestational diabetes mellitus. Diabetes Care. 2002;25:S94-6.
127 World Health Organization. Definition, diagnosis, and classification of diabetes mellitus and its complications. Geneva. World Health Organization. 1999. [pmcid: 325679].
128 Deerochanawong C, Putiyanun C, Wongsuryrat M, Serirat S, Jinayon P. Comparison of National Diabetes Data Group and World Health Organization criteria for detecting gestational diabetes mellitus. Diabetologia. 1996;39:1070-1073. [pmid: 8877291].
129 Pettitt DJ, Bennett PH, Hanson RL, Narayan KMV, Knowler WC. Comparison of World Health Organization and National Diabetes Data Group procedures to detect abnormalities of glucose tolerance during pregnancy. Diabetes Care. 1994;17:1264-1268. [pmid: 7821165].
130 Landon MB, Gabbe ST, Sachs L. Management of diabetes mellitus and pregnancy: a survey of obstetricians and maternal-fetal specialists. Obstet Gynecol. 1978;51:306-310. [pmid: 628532].
131 Moses RG, Griffiths RD. Can a diagnosis of gestational diabetes be an advantage to the outcome of pregnancy?. J Society Gynecol Investi. 1995;2:523-525.
132 Conway DL, Langer O. Elective delivery of infants with macrosomia in diabetic women: reduced shoulder dystocia versus increased cesarean deliveries. Am J Obstet Gynecol. 1998;178:922-925. [pmid: 9609560].
133 Coustan DR. Screening and testing for gestational diabetes mellitus. Obstet Gynecol Clin North Am. 1996;23:125-136. [pmid: 8684775].
134 Schaefer-Graf UM, Dupak J, Vogel M, et al Hyperinsulinism, neonatal obesity and placental immaturity in infants born to women with one abnormal glucose tolerance test value Journal of Perinatal Medicine 1998 261:27 36 9595364
135 Roberts RN, Moohan JM, Foo RL, Harley JM, Traub AI, Hadden DR. Fetal outcome in mothers with impaired glucose tolerance in pregnancy. Diabet Med. 1993;10:438-443. [pmid: 8334823].
136 Tallarigo L, Giampietro O, Penno G, et al. Relation of glucose tolerance to complications of pregnancy in non diabetic women. N Engl J Med. 1986;315:989-992. [pmid: 3762619].
137 Berkus MD, Langer O. Glucose tolerance test: degree of glucose abnormality correlates with neonatal outcome. Obstet Gynecol. 1993;81:344-348. [pmid: 8437783].
138 Lindsay MK, Graves W, Klein L. The relationship of one abnormal glucose tolerance test value and pregnancy complications. Obstet Gynecol. 1989;73:103-106. [pmid: 2909030].
139 Leikin EL, Jenkins JH, Pomerantz GA, et al. Abnormal glucose screening tests in pregnancy: a risk factor for fetal macrosomia. Obstet Gynecol. 1987;69. [pmid: 3822298].
140 Langer O, Brustman L, Anyaegbunam A, Mazze R. The significance of one abnormal glucose tolerance test value on adverse outcome in pregnancy. Am J Obstet Gynecol. 1987;157:758-763. [pmid: 3631178].
141 Troxler RG, Trabal JF, Malcolm CL. Interpretation of an abnormal glucose tolerance test encountered during multiphasic laboratory screening. Aviat Space Environ Med. 1975;46:729-735. [pmid: 1131139].
142 Rust OA, Bofill JA, Andrew ME, et al. Lowering the threshold for the diagnosis of gestational diabetes. Am J Obstet Gynecol. 1996;175:961-965. [pmid: 8885755].
143 Schwartz ML, Ray WN, Lubarsky SL. The diagnosis and classification of gestational diabetes mellitus: Is it time to change our tune?. Am J Obstet Gynecol. 1999;180:1560-1571. [pmid: 10368504].
144 Berkus MD, Langer O, Piper JM, Luther MF. Efficiency of lower threshold criteria for the diagnosis of gestational diabetes. Obstet Gynecol. 1995;86:892-896. [pmid: 7501334].
145 Schmidt M, Matos M, Reichett AAC, de Limas L, Duncan B. Prevalence of gestational diabetes mellitus - do the new WHO criteria make a difference?. Diabet Med. 2000;17:376-380. [pmid: 10872537].
146 McDonald GW, Fisher GF, Burnham C. Reproducibility of the oral glucose tolerance test. Diabetes. 1965;14:473-480. [pmid: 14334838].
147 Olefsky JM, Reaven GM. Insulin and glucose responses to identical oral glucose tolerance tests performed forty-eight hours apart. Diabetes. 1974;23:449-453. [pmid: 4830180].
148 Sermer M, Naylor CD, Gare DJ, et al. Impact of time since last meal on the gestational glucose challenge test. The Toronto Tri-Hospital Gestational Diabetes Project. Am J Obstet Gynecol. 1994;171:607-616. [pmid: 8092205].
149 Metzger BE. Summary and recommendations of the Third International Workshop Conference on gestational diabetes mellitus. Diabetes. 1991;40:197-201. [pmid: 1748259].
150 Sacks DA, Abu-Fadil S, Greenspoon JS, et al. How reliable is the fifty-gram one-hour glucose screening test?. Am J Obstet Gynecol. 1989;161:642-645. [pmid: 2782346].
151 Bartha JL, Martinez-Del-Fresno P, Comino-Delgado R. Gestational diabetes mellitus diagnosed during early pregnancy. Am J Obstet Gynecol. 2000;182:346-350. [pmid: 10694335].
152 Roberts AB, Baker JR, Metcalf P, et al. Fructosamine compared with a glucose load as a screening test for gestational diabetes. Obstet Gynecol. 1990;76:773-775. [pmid: 2216223].
153 Menon U, Ranjan M, Jasper P, et al. Evaluation of plasma fructosamine as a screening test for gestational diabetes. Aust NZ J Obstet Gynecol. 1991;31:25-26.
154 Corcoy R, Cerquiera MJ, Pedreno J, et al. Serum fructosamine is not a useful screening test for gestational diabetes. Eur J Obstet Gynecol Reprod Biol. 1990;38:217-220. [pmid: 2007448].
155 Comtois R, Desjarlais F, Nguyen M, et al. Clinical usefulness of estimation of serum fructosamine concentration as screening test for gestational diabetes. Am J Obstet Gynecol. 1989;160:651-654. [pmid: 2929687].
156 Cefalu WT, Prather KL, Chester DL, Wheeler CJ, Biswas M, Pernoll ML. Total serum glycosylated proteins in detection and monitoring of gestational diabetes. Diabetes Care. 1990;13:872-875. [pmid: 2209322].
157 Singer D, Samet J, Coley C, Nathan D. Screening for diabetes mellitus. Ann Intern Med. 1988. [pmid: 3138934].
158 Lind T. Antenatal screening using random blood glucose values. Diabetes. 1985;34:17-20. [pmid: 3996765].
159 Hatem M, Dennis KJ. A random plasma glucose method for screening abnormal glucose tolerance in pregnancy. Br J Obstet Gynaecol. 1987;94:213-216. [pmid: 3567116].
160 Hadden D. Evidence-based screening for gestational diabetes?. Diabet Med. 2000;17:402-404. [pmid: 10872544].
161 Li DF, Wong VC, O'Hoy KM, Yeung CY, Ma HK. Is treatment needed for mild impairment of glucose tolerance in pregnancy? A randomized controlled trial. Br J Obstet Gynaecol. 1987;94:851-4. [pmid: 3311138].
162 Bancroft K, Tuffnell DJ, Mason GC, Rogerson LJ, Mansfield M. A randomised controlled pilot study of the management of gestational impaired glucose tolerance. Br J Obstet Gynecol. 2000;107:959-963.
163 Walkinshaw SA. Dietary regulation for 'gestational diabetes'. Cochrane Database Syst Rev. 2000;2. CD000070.
164 Buchanan TS, Kjos SL, Montoro MN, et al. Use of fetal ultrasound to select metabolic therapy for pregnancies complicated by mild gestational diabetes. Diabetes Care. 1994;17:275-283. [pmid: 8026282].
165 Buchanan TA, Xiang AH, Kjos SL, Trigo E, Lee WP, Peters RK. Antepartum predictors of the development of type 2 diabetes in Latino women 11-26 months after pregnancies complicated by gestational diabetes. Diabetes. 1999;48:2430-2436. [pmid: 10580433].
166 Langer O, Anyaegbunam A, Brustman L, Divon M. Management of women with one abnormal oral glucose tolerance test value reduces adverse outcome in pregnancy. Am J Obstet Gynecol. 1989;161:593-599. [pmid: 2675597].
167 Shushan A, Ezra Y, Samueloff A. Early treatment of gestational diabetes reduces the rate of fetal macrosomia. Am J Perinatol. 1997;14:253-256. [pmid: 9259938].
168 Gyves MT, Rodman HM, Little AB, Fanaroff AA, Merkatz IR. A modern approach to management of pregnant diabetics: a two-year analysis of perinatal outcomes. Am J Obstet Gynecol. 1977;128:606-616. [pmid: 879221].
169 Kalkhoff RK Therapeutic results of insulin therapy in gestational diabetes mellitus Diabetes. 1985 34Suppl 2:97 100 3888749
170 Drexel H, Bichler A, Sailer S, et al. Prevention of perinatal morbidity by tight metabolic control in gestational diabetes mellitus. Diabetes Care. 1988;11:761-768. [pmid: 3073066].
171 Coustan DR, Imarah J. Prophylactic insulin treatment of gestational diabetes reduces the incidence of macrosomia, operative delivery, and birth trauma. Am J Obstet Gynecol. 1984;150:836-842. [pmid: 6391174].
172 Landon MB, Gabbe SG, Sachs L. Management of diabetes mellitus and pregnancy: a survey of obstetricians and maternal-fetal specialists. Obstet Gynecol. 1990;75:635-40. [pmid: 2179778].
173 Johnson JM, Lange IR, Harman CR, Torchia MG, Manning FA. Biophysical profile scoring in the management of the diabetic pregnancy. Obstet Gynecol. 1988;72:841-846. [pmid: 3054650].
174 Landon MB, Gabbe SG Antepartum fetal surveillance in gestational diabetes mellitus Diabetes. 1985 34Suppl 2:50 54 3888742
175 Girz BA, Divon MY, Merkatz IR. Sudden fetal death in women with well-controlled, intensively monitored gestational diabetes. J Perinatol. 1992;12:229-233. [pmid: 1432278].
176 Kjos SL, Leung A, Henry OA. Antepartum surveillance in diabetic pregnancies: predictors of fetal distress in labor. Am J Obstet Gynecol. 1995;173:1532-1539. [pmid: 7503197].
177 Landon MB, Gabbe SG. Fetal surveillance and timing of delivery in pregnancy complicated by diabetes mellitus. Obstet Gynecol Clin North Am. 1996;23:109-123. [pmid: 8684773].
178 Landon MB. Prenatal diagnosis of macrosomia in pregnancy complicated by diabetes mellitus. J Matern Fetal Med. 2000;9:52-4. [pmid: 10757436].
179 Manning F. Fetal biochemical and biophysical assessment. Diabetes Mellitus in Pregnancy. 2nd ed. Edinburgh: Churchill Livingstone. 1995;15:251-260.
180 Rouse DJ, Owen J, Goldenberg RL, Cliver SP. The effectiveness and costs of elective cesarean delivery for fetal macrosomia diagnosed by ultrasound. JAMA. 1996;276:1480-1486. [pmid: 8903259].
181 Harman CR, Menticoglou SM. Fetal surveillance in diabetic pregnancy. Current Opinion Obst Gynecol. 1997;9:83-90.
182 McLaren RA, Puckett JL, Chauhan SP. Estimators of birth weight in pregnant women requiring insulin: a comparison of seven sonographic models. Obstet Gynecol. 1995;85:567-569.
183 Levin AB, Lockwood CJ, Brown B, Lapinski R, Berkowitz RL. Sonographic diagnosis of the large for gestational age fetus at term: does it make a difference?. Obstet Gynecol. 1992;79:55-58. [pmid: 1727587].
184 Bernstein IM, Catalano PM. Examination of factors contributing to the risk of cesarean delivery in women with gestational diabetes. Obstet Gynecol. 1994;83:462-465. [pmid: 8127543].
185 Cohen B, Penning S, Major C, Ansley D, Porto M, Garite T. Sonographic prediction of shoulder dystocia in infants of diabetic mothers. Obstet Gynecol. 1996:849-854. [pmid: 8885926].
186 Buchanan TA, Kjos SL, Montoro MN, et al. Use of fetal ultrasound to select metabolic therapy for pregnancies complicated by mild gestational diabetes. Diabetes Care. 1994;17:275-283. [pmid: 8026282].
187 Rossi G, Somigliana E, Moschetta M, Bottani B, Barbieri M, Vignali M. Adequate timing fetal ultrasound to guide metabolic therapy in mild gestational diabetes mellitus. Acta Obstet Gynecol Scand. 2000;79:649-654. [pmid: 10949229].
188 Hopp H, Vollert W, Ragosch V, et al. Indication and results of insulin therapy for gestational diabetes mellitus. J Perinat Med. 1996;24:521-530. [pmid: 8950733].
189 Weiss PA, Hofmann HM, Kainer F, Haas JG. Fetal outcome in gestational diabetes with elevated amniotic fluid insulin levels. Dietary versus insulin treatment. Diabetes Res Clin Pract. 1988;5:1-7. [pmid: 3042342].
190 Fraser RB, Bruce C. Amniotic fluid insulin levels identify the fetus at risk of neonatal hypoglycemia. Diabet Med. 1999;16:568-572. [pmid: 10445832].
191 Star JA, Canick GE, Palomaki MW, et al. The relationship between second-trimester amniotic fluid insulin and glucose levels and subsequent gestational diabetes. Prenat Diagnosis. 1997;17:149-54.
192 Star J, Carpenter MW. The effect of pregnancy on the natural history of diabetic retinopathy and nephropathy. Clin Perinatol. 1998;25:887-916. [pmid: 9891621].
193 Haeusler MCH, Konstantiniuk P, Dorfer M, Weiss P. Amniotic fluid insulin testing in gestational diabetes: Safety and acceptance of amniocentesis. Am J Obstet Gynecol. 1998;179:917-920. [pmid: 9790370].
194 Carpenter MW, Canick JA, Star J, Carr SR, Burke ME, Shahinian K. Fetal hyperinsulinism at 14-20 weeks and subsequent gestational diabetes. Obstet Gynecol. 1996;87:89-93. [pmid: 8532274].
195 Schaefer UM, Songster G, Xiang A, Berkowitz K, Buchanan TA, Kjos SL. Congenital malformations in offspring of women with hyperglycemia first detected during pregnancy. Am J Obstet Gynecol. 1997;177:1165-1171. [pmid: 9396914].
196 Kalter H. The non-teratogenicity of gestational diabetes. Paediatr Perinat Epidemiol. 1998;12:456-458. [pmid: 9805717].
197 Kjos SL, Buchanan TA Gestational diabetes mellitus New Engl J Med. 1999 341(23):1749 1756 10580075
198 Berkowitz K, Reyes C, Saadat P, Kjos SL. Fetal lung maturation. Comparison of biochemical indices in gestational diabetic and nondiabetic pregnancies. J Reprod Med. 1997;42:793-800. [pmid: 9437594].
199 Kjos SL, Walther FJ, Montoro M, Paul RH, Diaz F, Stabler M. Prevalence and etiology of respiratory distress in infants of diabetic mothers: predictive value of fetal lung maturation tests. 1990;163:898-903. [pmid: 2144951].
200 Piper JM, Langer O. Does maternal diabetes delay fetal pulmonary marturity?. Am J Obstet Gynecol. 1993;168:783-786. [pmid: 8456880].
201 Coustan DR. Management of gestational diabetes mellitus: a self-fulfilling prophecy?. JAMA. 1996;275:1199-1200. [pmid: 8609690].
202 Kerbel D, Glazier R, Holzapfel S, Yeung M, Lofsky S. Adverse effects of screening for gestational diabetes: a prospective cohort study in Toronto, Canada. J Med Screen. 1997;4:128-132. [pmid: 9368868].
203 Sjogren B, Robeus N, Hansson U. Gestational diabetes: a case-control study of women's experience of pregnancy, health and the child. J Psychosomatic Res. 1994;38:815-822.
204 Langer N, Langer O. Emotional adjustment to diagnosis and intensified treatment of gestational diabetes. Obstet Gynecol. 1994;84:329-334. [pmid: 8058225].
205 Spirito A, Williams C, Ruggiero L, Bond A, McGarvey ST, Coustan D. Psychological impact of the diagnosis of gestational diabetes. Obstet Gynecol. 1989;73:562-566. [pmid: 2648224].
206 Feig DS, Chen E, Naylor CD. Self-perceived health status of women three to five years after the diagnosis of gestational diabetes: A survey of cases and matched controls. Am J Obstet Gynecol. 1998;178:386-393. [pmid: 9500504].
207 Knopp RH, Magee MS, Raisys V, Benedetti T, Bonet B. Hypocaloric diets and ketogenesis in the management of obese gestational diabetic women. J Am Coll Nutr. 1991;10:649-667. [pmid: 1770194].
208 Galtier-Dereure F, Boegner C, Bringer J. Obesity and pregnancy: complications and cost. Am J Clin Nutr. 2000;71:1242S-1248S. [pmid: 10799397].
209 Kitzmiller JL. Cost analysis of diagnosis and treatment of gestational diabetes mellitus. Clin Obstet Gynecol. 2000;43:140-153. [pmid: 10694996].
210 Gilby JR, Williams MC, Spellacy WN. Fetal abdominal circumference measurements of 35 and 38 cm as predictors of macrosomia. A risk factor for shoulder dystocia. J Reprod Med. 2000;45:936-8. [pmid: 11127108].
211 Kitzmiller JL, Elixhauser A, Carr S, et al. Assessment of costs and benefits of management of gestational diabetes mellitus. Diabetes Care. 1998;21:B123-B130. [pmid: 9704239].
212 Williams CB, Iqbal S, Zawacki CM, Yu D, Brown MB, Herman WH. Effect of selective screening for gestational diabetes. Diabetes Care. 1999;22:418-421. [pmid: 10097921].
213 Buchanan TA, Kjos SL, Schafer U, et al Utility of fetal measurements in the management of gestational diabetes mellitus Diabetes Care. 1998 21Suppl 2:B99 106 9704235
214 Buchanan TA, Xiang A, Kjos SL, et al. Gestational diabetes: antepartum characteristics that predict postpartum glucose intolerance and type 2 diabetes in Latino women. Diabetes. 1998;47:1302-1310. [pmid: 9703332].
215 Harris R, Donahue K, Rathore S, Frame P, Woolf S, Lohr KN. Screening Adults for Type 2 Diabetes: A Review of the Evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;138:215-229. [pmid: 12558362].