# Methods

## Analytic Framework and Key Questions

Members of the RTI International-University of North Carolina (UNC) Evidence-based Practice Center (RTI-UNC EPC), together with 2 liaison members of the US Preventive Services Task Force (USPSTF) (see acknowledgments in Appendix A), developed an analytic framework to specify the key questions relevant to the issues of screening for and treatment of gestational diabetes mellitus (GDM). The analytic framework describes the relationships among screening a population at risk (starting on the left of the figure), diagnosing and then treating patients (the middle panels of the figure), and realizing one or more sets of desired outcomes (on the right side of the figure), in this case decreased incidence and severity of maternal and infant morbidity (Figure 1). Numbers in superscripts in the analytic framework correspond to six key questions that guided the literature searches and analysis.

Figure 1. Screening for Gestational Diabetes: Analytic Framework

The six key questions for this work are as follows:

- Key Question No. 1. What are the health consequences for mothers and infants of screening for gestational diabetes? Both the type and the magnitude of such outcomes are of concern. For mothers, specific outcomes include perineal injuries (such as third or fourth degree lacerations), cesarean section, anesthesia risks, and pregnancy-induced hypertension (PIH). For infants, outcomes of interest include hypoglycemia that requires treatment, hyperbilirubinema that requires treatment, brachial plexus injuries, fractures of the clavicle, admissions to special care nurseries, and stillbirth.
- Key Question No. 2. What are the health consequences of untreated gestational diabetes?
- Key Question No. 3. What are the accuracy and reliability of GDM screening tests? In this case, accuracy is considered largely in terms of sensitivity and specificity.
- Key Question No. 4. What is the efficacy or effectiveness of glycemic control or antepartum testing and surveillance, or both, in terms of maternal and infant outcomes? With respect to glycemia control, 4 intermediate outcomes are of interest: macrosomia, operative delivery, neonatal hypoglycemia, and neonatal hyperbilirubemia (both by biochemical assays). Generally these issues are couched in terms of the outcomes for screened women versus those for women who are not screened; where differences occur, what they are and their magnitude are then the important matters. The same approach holds for comparisons of women who do or do not receive antepartum testing and surveillance.
- Key Question No. 5. What are the harms of screening? What are the harms of treatment?
- Key Question No. 6. What are the costs and cost-effectiveness of screening and treatment for GDM versus not screening or not treating.

The GDM analytic framework in Figure 1 depicts 2 approaches for connecting screening with improved health outcomes. The first entails direct evidence (Key Question 1) linking screening to the specified maternal outcomes. The second entails more indirect evidence arrived at by piecing together several bodies of evidence (via Key Questions 3, 4, 5) concerning the accuracy and reliability of screening tests and the efficacy or effectiveness of treatment (specifically, glycemic control) or antepartum testing and surveillance. For both screening and the two treatment interventions (glycemic control or testing and surveillance), costs and cost-effectiveness are relevant concerns (Key Question 6). Finally, Key Question 2 about the impact of untreated GDM provides a context within which to interpret all these issues.

## Literature Search and Analysis Strategy

### Inclusion/Exclusion Criteria for Admissible Evidence

We developed inclusion criteria for selecting the evidence relevant to answer the key questions (Table 2). We required randomized controlled trials (RCTs) for direct evidence for the efficacy of screening, treatment, and harms associated with treatment. Although we examined evidence of the effects of treatment on intermediate outcomes (i.e., those specified for Key Question 4 -- macrosomia, operative delivery, neonatal hypoglycemia or hyperbilirubinemia), we prioritized studies that included health outcomes of the types shown in the boxes on the far right of the analytic framework for both mothers and infants (e.g., maternal trauma, brachial plexus injury, treatment-requiring hypoglycemia). For material on the sensitivity, specificity, and reliability of GDM screening tests, we required that articles provide data by which we could calculate sensitivity and specificity (if not reported directly by the article) and that the studies have used a criterion or reference standard. We allowed any study design for articles relating to harms and costs. All searches started with exploding the term "diabetes, gestational" and then proceeded by adding further terms.

Table 2. Inclusion Criteria, Search Strategy, and Results of Searches for Six Key Questions on Screening for Gestational Diabetes Mellitus

Key Question | Inclusion Criteria* | Number of Articles Meeting Criteria
1. Screening efficacy for maternal and fetal health outcomes | RCT Screening for GDM Maternal or infant health outcomes | 0
2. Adverse health outcomes of untreated GDM | RCT Screening for GDM Maternal or infant health outcomes | 9
3. Accuracy and reliability of screening tests | Screening test for GDM Data available to calculate sensitivity and specificity Criterion standard used | 13
4. Treatment for GDM: | RCT | 9
- Glycemic control | Glycemic control Health outcomes
- Antepartum surveillance | RCT Surveillance or antepartum health outcomes | 5
5. Harms of screening and harms of treatment | Any research design Any harm associated with either screening or treatment of GDM | 9
6. Costs and cost-effectiveness of screening or treatment, efficiency of screening | Any research design Costs, efficiency of screening for GDM | 7

* All searches started with exploding "diabetes, gestational."

Note: GDM indicates gestational diabetes mellitus; RCT, randomized clinical trial.

Review of the literature was guided by our key questions and these inclusion criteria. We examined the critical literature from the 1996 USPSTF review^ 14 ^ and searched MEDLINE and the Cochrane Library for systematic reviews and relevant studies published in English between January 1, 1994 and December 15, 2001. We also examined the bibliographies of pertinent articles and contacted experts. We especially looked for studies concerning groups whose experience is clearly generalizable to the US population. We also conducted focused searches of MEDLINE from 1966 through 1994 to identify older articles of interest.

### Study Selection

The first author reviewed abstracts of all articles found in the searches to determine which ones met inclusion criteria. The second author reviewed all abstracts excluded by the first. The authors retrieved the full text of all articles not excluded by both of these reviewers.

The first author reviewed the full text of all retrieved articles against inclusion criteria and discussed all excluded articles with the second author. They included any article that either author judged to have met the inclusion criteria (see last column in Table 2).

### Synthesis of the Literature

The first author abstracted data from all these articles and entered those data into predesigned evidence tables. (Evidence tables appear in Appendix B.) USPSTF criteria was used for judging the quality of individual studies,^ 20 ^ and both authors agreed to the final grading. Throughout the review, the authors worked closely with the USPSTF liaisons assigned to this topic.

### Preparation of this Systematic Evidence Review

The authors presented an initial work plan for this SER and interim reports (including a full draft of this SER) at several meetings of the USPSTF in 2001, receiving feedback at each stage. Throughout the development of the SER, the material was also discussed with the TF liaisons. Finally, we sent the draft SER to multiple external peer reviewers (see Appendix A) and revised the SER as appropriate into this final version.