# Appendix B: Evidence Tables

Glossary for Evidence Tables

BMI | Body Mass Index
EFW | Estimated Fetal Weight
FBS | Fasting Blood Sugar
g | Gram
GCT | Glucose Challenge Test
GDM | Gestational Diabetes Mellitus
GTT | Glucose Tolerance Test
h | Hour
l | Liter
LGA | Low for Gestational Age
mmol | Millimol
NDDG | National Diabetes Data Group
NICU | Neonatal Intensive Care Unit
RCT | Randomized Controlled Trial

Evidence Table 1. Efficacy of Screening for Gestational Diabetes Mellitus

Source: Author, Year | Research Design and Randomization | Subjects | Measurements | Intervention | Results | | Comments
Source: Author, Year | Research Design and Randomization | Subjects | Measurements | Intervention | Obstetrical Outcomes | Neonatal Outcomes | Comments
Griffin et al., 2000^ 21 ^ | Prospective RCT: universal screening versus risk factor screening | Universal screening: n = 1,889 Selective screening: n = 1,853 | Universal: 1-h 50-g GCT at 26-28 weeks If plasma glucose >7.8 mmol/l then 3-h 100-g oral GTT Risk factor: 3-h 100-g oral GTT at 32 weeks If a risk factor is present, repeat GCT at 32 weeks if GCT normal or had been abnormal but with normal oral GTT | GDM subjects referred to combined care clinic of obstetrician and endocrinologist Uniform diabetic and obstetrical management | Total with GDM: Universal: 1.45% (n = 27) Risk factor: 2.7% (n = 35 GDM) Mean gestational age at diagnosis: Universal: 30+2.6 weeks Risk factor: 33+3.7 weeks | Comparison of GDM patients in two groups: Term spontaneous vaginal delivery: Universal: 77% Risk factor: 56% Emergency cesarean delivery: Universal: 11.4% Risk factor: 18.5% Delivery at <37 weeks: Universal: 2.9% Risk factor: 18.5% Birth weight:>4500g: Universal: 0% Risk factor: 11.1% NICU admission: Universal: 2.9% Risk factor: 18.5% Hyperbilirubinemia: Universal: 2.9% Risk factor: 14.8% No fetal losses in either group with GDM | Grade: Poor No data on lost patients (i.e., 32/249 in risk factor group with no oral GTT) or on refusals Testing/intervention done at different gestational ages for the two groups "Control" group a combination of non-GDM subjects from each group No intention-to-screen analysis

Evidence Table 2. Impact of Treatment of Gestational Diabetes Mellitus

Source: Author, Year | Research Design and Randomization | Subjects | Measurements | Intervention | Results | | Comments
Source: Author, Year | Research Design and Randomization | Subjects | Measurements | Intervention | Obstetrical Outcomes | Neonatal Outcomes | Comments
Garner et al., 1997^ 36 ^ | Prospective RCT (pilot study). Primary objective: Determine if strict maternal glycemic control in treatment of GDM lessens the risk of macrosomia | n = 149 GDM in treatment arm n = 150 GDM controls "Control Failures" (FBS >140 mg/dl, 1-hr post prandial>200): n = 16 in control group (10.6%); n = 13 in treatment group (8.7%) with same values | 75-g glucose screening test between 24-28 weeks' gestation with a 1-hr postscreen cutoff level of 144 mg/dL. If positive screen, underwent oral GTT with 75-g glucose load; diagnosed GDM by application of Hatem, et al., 1987 | Treatment group:; 1. Follow-up in tertiary care setting with obstetrician and endocrinologist; 2. Initial dietary counseling, calorie-restricted diet; 3. Taught home glucose monitoring; if fasting glucose levels <80 mg/dl and 1 hour postprandial glucose levels <140 mg/dl on > 2 occasions, insulin treatment started; 4. Seen biweekly, biophysical profile and ultrasound each visit; Controls:; 1. Returned to primary obstetrical care provider; 2. Not seen by dietician; 3. 2 glucose levels checked weekly at home; results telephoned to independent observer; 4. No high-risk fetal monitoring unless indicated; Failed control group: Transferred to treatment arm and placed on diet, insulin, fetal monitoring | Mean maternal weight gain similar Treatment arm: 24.2% required insulin Treatment group had significantly lower preprandial and 1-hour postprandial glucose levels by 30 to 32 weeks' gestation, which continued until term (36-38 weeks) No difference between groups in mode of delivery (P = >0.8) | No difference between groups (P >0.1) in mean birth weight, hyperbilirubinemia, or hypoglycemia No stillbirths, neonatal deaths, congenital anomalies or birth trauma in either group Neonatal hypocalcemia: Control: 30%; Treated: 40.9% (P = 0.048) No significant difference in other maternal and fetal outcomes | Grade: Fair n = 300 does not reach the statistical power to detect many differences Control women not masked to results of GDM screen and follow-up glucose testing results; may have led to self-education on diet therapy and self-treatment by modification of diet. Primary obstetrical care providers also not masked to results; may play a role in cesarean section rates if diagnosis was known
de Veciana et al., 1995^ 106 ^ | RCT Primary objective: To compare the efficacy of postprandial versus preprandial monitoring in achieving glycemic control in women with insulin-requiring GDM | n = 66 women with GDM who required insulin therapy. All pregnant women who had risk factors for GDM screened at initial visit or if negative screen, rescreened at 24-28 weeks No difference between two groups with regard to age, gravidity, race/ethnicity, prepregnancy weight, BMI, weeks of gestation at diagnosis | Goals: Preprandial 60-105 mg/dL Postprandial <140 mg/dL. Initial screening: 1-hour plasma glucose after a 50-g glucose oral load; if >140 mg/dL and 190 mg/dL, then 3-hour 100-g oral GTT GDM diagnosed if >2 plasma glucose values were abnormal: FBS >105 mg/dL 1-hour >190 mg/dL 2-hour >165 mg/dL 3-hour >145 mg/dL If initial GCT value >190 mg/dL, classified as GDM and monitored with fasting and postprandial glucose values to determine need for insulin therapy | GDM patients treated with diet and monitoring Insulin therapy started if FBS >105 mg/dL or postprandial values >140 mg/dL or if had elevated FBS at 3-hour oral GTT Preprandial monitoring plan: daily monitoring of fasting, preprandial, and bedtime capillary glucose concentration. Postprandial monitoring plan: Daily monitoring of fasting blood glucose concentration and 1 hour after each meal | No significant difference between groups with regards to gestational age at delivery, maternal weight gain, hospitalizations for glycemic control, or pre-eclampsia Glycosylated hemoglobin (%) comparable at initiation of insulin therapy but was lower in postprandial group prior to delivery | Birth weight: Preprandial: 3,848 g Postprandial: 3,469 g Shoulder dystocia: Preprandial: 18% Postprandial: 3% Neonatal hypoglycemia: Preprandial: 21% Postprandial: 3% No difference in small for gestational age, hyperbilirubinemia, apgar score of < 7, or stillbirths | Grade: Fair Unknown number of refusals Clinicians not masked; may impact on obstetrical outcomes Predominantly Hispanic population Because GDM was diagnosed early in pregnancy, some women may have had previously undiagnosed type 2 diabetes Exclusion of women started on insulin therapy after 30 weeks' gestation increased the likelihood that a difference in perinatal outcomes would be found between the two groups
Buchanan, et al., 1994^ 164 ^ | RCT of diet versus diet plus insulin in Latina women with GDM and fetal ultrasound abdominal circumferrence >75th percentile n = 59 randomized to: diet (n = 29); diet plus twice daily insulin (n = 30) | n = 73 randomized n = 59 completed RCT | Nonstress tests twice weekly if fasting glucose levels before diet therapy >105 mg/dL; once at > 34 weeks' gestation All others started non-stress tests at 40 weeks' gestation. Heel capillary blood from infants All infants examined by neonatologist within 24 hours of birth | All subjects met with dietary staff; were taught to monitor capillary glucose levels Weekly outpatient clinic visits Diet only managed by routine obstetrical service; diet plus insulin managed by high-risk service Standard obstetrical guidelines followed for all patients | Symptomatic hypoglycemic episodes Diet only: 0 Diet plus insulin: 0.3 per patient-week Glycemic control in diet plus insulin (6-9mg/dl) better than in diet only (P< 0.005) | Same mean gestational age at delivery Diet only had higher mean birth weight than diet plus insulin No significant birth trauma in either group No differences in mean infant glucose levels or rates of hypoglycemia during first 3 hours of life | Grade: Fair Obstetrical management not standardized Small sample size Question clinical significance of birth weight difference Cesarean delivery rates did not parallel LGA rates or birth weights; may reflect difference in intrapartum management
Nachum et al., 1999^ 105 ^ | RCT Primary objective: Compare twice daily versus four times daily insulin to treat GDM and pregestational diabetes | n = 138 received insulin four times daily n = 136 received insulin twice daily n = 118 patients with pregestational diabetes Insulin treatment began prior to 35 weeks gestation GDM diagnosed by NDDG criteria | Monthly HbA1c Capillary whole blood glucose 7 times daily until adequate control, then at least twice daily | Four times daily regimen: Three doses of regular insulin before meals; intermediate dose at bedtime Twice daily regimen: Combination of regular and intermediate insulin morning and evening Standardized obstetrical management Standardized neonatal care, close monitoring | Glycemic control: Four times daily group had improved glycemic control compared to twice daily group Adequate glycemic control achieved in 17% more women in four times daily group than in twice daily group No statistically significant differences in gestational age at delivery, maternal weight gain, cesarean sections, or pregnancy-induced hypertension | Hypoglycemia: Four times daily: 0.7% Twice daily: 5.9% Hyperbilirubinemia: Four times daily: 21% Twice daily: 11% "Overall neonatal morbidity": Four times daily: 29% Twice daily: 17% No significant difference in mean birth weight, perinatal mortality, major congenital anomalies, small or large for gestational age, macrosomia, Apgar score <7, hyaline membrane disease, polycythemia, or birth trauma (peripheral nerve damage, bone fracture) | Grade: Good Improvement in overall neonatal morbidity statistic comprised almost entirely of decrease in hypoglycemia and hyperbilirubinemia, as other factors not significantly different between the groups No data provided on the treatment required (if any) for those neonates with hypoglycemia or hyperbilirubinemia

Evidence Table 3. Impact of Antepartum Testing and Surveillance

Source: Author, Year | Research Design and Randomization | Subjects | Measurements | Intervention | Results | | Comments
Source: Author, Year | Research Design and Randomization | Subjects | Measurements | Intervention | Obstetrical Outcomes | Neonatal Outcomes | Comments
Hopp, et al., 1996^ 188 ^ | Prospective RCT Primary objective: Compare the amniotic fluid insulin concentration (AFI) to the mean maternal blood glucose (MBG) for managing GDM. | n = 123 women diagnosed with GDM. Group A: n = 61 Group B: n = 62 (see intervention) | Diurnal and nocturnal measurement of fasting, pre- and postprandial blood glucose levels | Group A: Managed according to the amniotic fluid insulin concentration. Group B: Managed only on the basis of mean blood glucose. All subjects hospitalized initially; provided comprehensive education program; placed on dietary regimen; taught self-monitoring of capillary whole-blood glucose levels; readmitted every 3 weeks for 24-hour blood glucose profile and HbA1c | Glycemic control equal in both groups No difference between the two groups regarding miscarriage, stillbirth, or neonatal death No difference in severe pre-eclampsia, urinary tract infection, preterm labor, premature delivery, or delivery at <37 weeks or >37 weeks | Large for gestational age: Group A: 4.9% Group B: 35.4% Neonatal hypoglycemia: Group A: 13.1% Group B: 27.4% (No difference in hyperbilirubinemia or hypocalcemia) | Grade: Fair Complication rate of amniocentesis (0.5% to 1%) Physicians managing labor not masked
Rossi et al., 2000^ 187 ^ | RCT Primary Objective: Investigate the adequate timing for ultrasound assessment of abdominal circumference (AC) early in the 3rd trimester to use as a guide for initiation of insulin | n=141 women with mild GDM n=73 evaluated at both 28 and 32 weeks' gestation n=68 evaluated at 32 weeks' gestation only n=29 with abdominal circumference >75th percentile | Ultrasound measurement of fetal abdominal circumference done by staff unaware of the hypothesis being tested in the study Group A: 28 and 32 weeks' gestation Group B: 32 weeks' gestation Frequent neonatal monitoring | Insulin started for both groups if abdominal circumference >75th percentile Diet and instruction for daily multiple self-monitoring of capillary blood glucose Weekly obstetrical care Labor induced before 42 completed weeks gestation, EFW >4,000 g and other maternal, fetal, or abnormal labor indications | n = 29 (21%) placed on insulin therapy based on fetal abdominal circumference > 75th percentile; no hypoglycemia episodes No statistically significant differences with regard to: gestational age at delivery; spontaneous vaginal delivery; cesarean delivery; vacuum use; 5 minute Apgar <7; neonatal hypoglycemia, hypocalcemia, or hyperbilirubinemia | Macrosomic infants: Group A: 33.3%; Group B: 71.4% (P < 0.05.) Macrosomic rate 11.1% in Group A cases where insulin started by 28 weeks | Grade: Fair Error of abdominal circumference measurement on ultrasound 60% of fetuses with abdominal circumference >75th percentile at 32 weeks in Group A (60%) met this threshold at 28 weeks No control group without insulin prophylaxis so the effectiveness of insulin therapy in preventing macrosomia in those with abdominal circumference >75th percentile could not be assessed The effectiveness of insulin therapy in this study is indirect Small number of women in trial