# Appendix A: Acknowledgements

This study was developed by the RTI-UNC Evidence-based Practice Center under contract to the Agency for Healthcare Research and Quality (Contract No. 290-97-0011), Rockville, Maryland.

We thank David Atkins, MD, MPH, Chief Medical Officer for the Center for Practice Technology and Assessment, and Jean Slutsky, PA, MSPH, the project officer for this project, both at the Agency for Healthcare Research and Quality for their assistance throughout the project.

We are especially indebted to Loraine Monroe of RTI International for superior word processing support.

In addition, we would like to thank our US Preventive Services Task Force topic liaisons, Mark Johnson, MD, MPH, UMD-New Jersey Medical School, Newark, NJ and Jeffrey Peipert, MD, MPH, Women and Infants Hospital, Providence, RI for their guidance during this project.

An earlier version of this systematic review underwent extensive external peer review in 2000. We thank the following peer reviewers for helpful comments and suggestions: Denice Feig, MD, MSc, FRCPC, Mt Sinai Hospital, Toronto, Ontario; Michael L. LeFevre, MD, MSPH, University of Missouri School of Medicine, Columbia MO; Benjamin Sachs, DrPH, MD, Beth Israel Deaconess Medical Center, Boston, MA; Marian L. Parrot, MD, MPH, American Diabetes Association, Alexandria, VA; Boyd E. Metzger, MD, Northwestern University, Chicago, IL; Matthew Sermer, MD, Mount Sinai Hospital, Toronto, Ontario; Donald Coustan, MD, Brown University, Providence, RI; David A. Grimes, Family Health International, Research Triangle Park, NC; Michael M. Engelgau, Centers for Disease Control and Prevention, Atlanta, GA.