# References

1 Ries LAG, Eisner MP, Kosary CL, et al., Editors. SEER Cancer Statistics Review 1973-1997. Bethesda, MD: National Cancer Institute. 2000. [pmcid: 384376].
2 International Agency for Research on Cancer (IARC) Working Group on the Evaluation of Cervical Cancer Screening Programmes. Screening for squamous cervical cancer: duration of low risk after negative results of cervical cytology and its implication for screening policies. Br Med J. 1986;293:659-664. [pmid: 3092971].
3 Sasieni PD, Cuzick J, Lynch-Farmery E. Estimating the efficacy of screening by auditing smear histories of women with and without cervical cancer. The National Co-ordinating Network for Cervical Screening Working Group. Br J Cancer. 1996;73:1001-1005. [pmid: 8611418].
4 United States Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Alexandria, VA: International Medical Publishing, Inc. 1996. [pmcid: 190016].
5 Landis SH, Murray T, Bolen S, Wingo PA. Cancer Statistics, 1999. CA- Cancer J Clin. 1999;49:8-31. [pmid: 10200775].
6 Daly MB, Bookman MA, Lerman CE; Female reproductive tract: cervix, endometrium, ovary. Greenwald P, Kramer BS, Weed DL, Editors. Cancer Prevention and Control. New York, NY: Marcel Dekker. 1995. [pmcid: 441483].
7 Washington, DC: U.S. Dept. of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Center for Health Statistics. 1995. [pmcid: 441483].
8 Schottenfeld D, Fraumeni JFe. Cancer Epidemiology and Prevention. 2nd ed. New York: Oxford University Press. 1996. [pmcid: 190016].
9 de Vet HCW, Sturmans F, Knipschild PG The role of cigarette smoking in the etiology of cervical dysplasia Epidemiology. 1994 5(6):631 633 7841245
10 Winkelstein W. Smoking and cervical cancer -- current status: a review. Am J Epidemiol. 1990;131:945-957. [pmid: 2188500].
11 Lyon JL, Gardner JW, West DW, Stanish WM, Hebertson RM. Smoking and carcinoma in situ of the uterine cervix. Am J Public Health. 1983;73:558-562. [pmid: 6837821].
12 Magnusson PE, Sparen P, Gyllensten U. Genetic link to cervical tumours. Nature. 1999;400:29-30. [pmid: 10403244].
13 International Agency for Research on Cancer (IARC). Monograph on the evaluation of carcinogenic risk to humans, vol. 64. Lyons: IARC; 199564.
14 Bosch FX, Manos MM, Munoz N, et al J Natl Cancer Inst. 1995 87(11):796 802 7791229
15 Jacobs MV, Snijders PJ, van den Brule AJ, Helmerhorst TJ, Meijer CJ, Walboomers JM. A general primer GP5+/GP6(+)-mediated PCR-enzyme immunoassay method for rapid detection of 14 high-risk and 6 low-risk human papillomavirus genotypes in cervical scrapings. J Clin Microbiol. 1997;35:791-795. [pmid: 9041439]. [pmcid: 229677].
16 Burk RD, Ho GY, Beardsley L, Lempa M, Peters M, Bierman R Sexual behavior and partner characteristics are the predominant risk factors for genital human papillomavirus infection in young women J Infect Dis. 1996 174(4):679 689 8843203
17 Dillner J, Kallings I, Brihmer C, et al Seropositivities to human papillomavirus types 16, 18, or 33 capsids and to Chlamydia trachomatis are markers of sexual behavior J Infect Dis. 1996 173(6):1394 1398 8648211
18 Schiffman MH, Brinton LA. The epidemiology of cervical carcinogenesis. Cancer. 1995;76:1888-1901. [pmid: 8634980].
19 Meijer CJ, Helmerhorst TJ, Rozendaal L, van der Linden JC, Voorhorst FJ, Walboomers JM. HPV typing and testing in gynaecological pathology: has the time come?. Histopathology. 1998;33:83-86. [pmid: 9726055].
20 Rosenthal DL, Acosta D, Peters RK. Computer-assisted rescreening of clinically important false negative cervical smears using the PAPNET Testing System. Acta Cytologica. 1996;40:120-126. [pmid: 8604564].
21 Cuzick J, Sasieni P, Davies P, et al. Systematic Review of the Role of Human Papillomavirus Testing Within a Cervical Cancer Screening Program. Health Technol Assess. 1999;3:I-IV and 1-196. [pmid: 10530393].
22 Park T, Fujiwara H, Wright TC. Molecular biology of cervical cancer and its precursors. Cancer. 1995;76:1902-1913. [pmid: 8634981].
23 Koutsky L. Epidemiology of genital human papillomavirus infection. Am J Med. 1997;102:3-8. [pmid: 9217656].
24 Hildesheim A, Hadjimichael O, Schwartz PE, et al. Risk factors for rapid-onset cervical cancer. Am J Obstet Gynecol. 1999;180:571-577. [pmid: 10076130].
25 Janerich DT, Hadjimichael O, Schwartz PE, et al. The screening histories of women with invasive cervical cancer, Connecticut. Am J Public Health. 1995;85:791-794. [pmid: 7762711].
26 Sawaya GF, Kerlikowske K, Lee NC, Gildengorin G, Washington AE. Frequency of cervical smear abnormalities within 3 years of normal cytology. Obstet Gynecol. 2000;96:219-223. [pmid: 10908766].
27 Martin-Hirsch P, Lilford R, Jarvis G, Kitchener HC. Efficacy of cervical-smear collection devices: a systematic review and meta-analysis [published erratum appears in Lancet 2000 Jan 29;355(9201):414]. Lancet. 1999;354:1763-1770. [pmid: 10577637].
28 Acta Cytologica. 1993 37(2):115 124 8465628
29 Richart RM. Cervical intraepithelial neoplasia. Pathol Annu. 1973;8:301-328. [pmid: 4583016].
30 Reagan JW, Fu YS. Histologic types and prognosis of cancers of the uterine cervix. Int J Radiat Oncol Biol Phys. 1979;5:1015-1020. [pmid: 229090].
31 Nyirjesy I. Atypical or suspicious cervical smears. An aggressive diagnostic approach. J Am Med Assoc. 1972;222:691-693.
32 McCrory DC, Mather DB, Bastian L. Evaluation of Cervical Cytology: Evidence Report Number 5, Summary. Agency for Health Care Policy and Research. Rockville, MD: Agency for Health Care Policy and Research. 1999. [pmid: 10051999]. [pmcid: 325679].
33 Harris RP, Helfand M, Woolf SH, et al Current Methods of the US Preventive Services Task Force: A Review of the Process Am J Prev Med. 2001 2(3S):21 35
34 Kainz C, Gitsch G, Heinzl H, Breitenecker G. Incidence of cervical smears indicating dysplasia among Austrian women during the 1980s. Br J Obstet Gynaecol. 1995;102:541-544. [pmid: 7647055].
35 Gram IT, Macaluso M, Stalsberg H. Incidence of cervical intraepithelial neoplasia grade III, and cancer of the cervix uteri following a negative Pap-smear in an opportunistic screening. Acta Obstet Gynecol Scand. 1998;77:228-232. [pmid: 9512333].
36 Sawaya GF, Kerlikowske K, Lee NC. When can cervical cancer screening intervals be lengthened? Outcomes following 1, 2, and 3 or more normal cervical smears. (unpublished data).
37 Forsmo S, Jacobsen BK, Stalsberg H. Cervical neoplasia in pap smears: risk of cervical intra-epithelial neoplasia (CIN) after negative or no prior smears in a population without a mass screening programme. Int J Epidemiol. 1996;25:53-58. [pmid: 8666505].
38 Gustafsson L, Sparen P, Gustafsson M, et al. Low efficiency of cytologic screening for cancer in situ of the cervix in older women. Int J Cancer. 1995;63:804-809. [pmid: 8847138].
39 Cruickshank ME, Angus V, Kelly M, McPhee S, Kitchener HC. The case for stopping cervical screening at age 50. Brit J Obstet Gynaecol. 1997;104:586-589. [pmid: 9166202].
40 Lawson HW, Lee NC, Thames SF, Henson R, Miller DS. Cervical cancer screening among low-income women: results of a national screening program, 1991-1995. Obstet Gynecol. 1998;92:745-752. [pmid: 9794662].
41 Cecchini S, Ciatto S, Zappa M, Biggeri A. Trends in the prevalence of cervical intraepithelial neoplasia grade 3 in the district of Florence, Italy. Tumori. 1995;81:330-333. [pmid: 8804448].
42 Mitchell HS, Giles GG. Cancer diagnosis after a report of negative cervical cytology [see comments]. Med J Aust. 1996;164:270-273. [pmid: 8628160].
43 Sigurdsson K. Trends in cervical intra-epithelial neoplasia in Iceland through 1995: evaluation of targeted age groups and screening intervals. Acta Obstet Gynecol Scand. 1999;78:486-492. [pmid: 10376857].
44 Sawaya GF, Grady D, Kerlikowske K, et al. The positive predictive value of cervical smears in previously-screened postmenopausal women: the Heart and Estrogen/progestin Replacement Study (HERS). Ann Intern Med. 2000;133:942-950. [pmid: 11119395].
45 Miller AB, Visentin T, Howe GR. The effect of hysterectomies and screening on mortality from cancer of the uterus in Canada. Int J Cancer. 1981;27:651-657. [pmid: 7287225].
46 Eaker ED, Vierkant RA, Konitzer KA, Remington PL. Cervical cancer screening among women with and without hysterectomies. Obstet Gynecol. 1998;91:551-555. [pmid: 9540939].
47 Fox J, Remington P, Layde P, Klein G. The effect of hysterectomy on the risk of an abnormal screening Papanicolaou test result. Am J Obstet Gynecol. 1999;180:1104-1109. [pmid: 10329862].
48 Pearce K, Haefner H, Sarwar S, Nolan T. Cytopathological findings on vaginal Papanicolaou smears after hysterectomy for benign gynelogical disease. N Engl J Med. 1996;335:1559-1562. [pmid: 8900088].
49 Weintraub J, Morabia A. Efficacy of a liquid-based thin layer method for cervical cancer screening in a population with a low incidence of cervical cancer. Diagn Cytopathology. 2000;22:52-59.
50 Nanda K, McCrory DC, Myers ER, et al. Accuracy of the Papanicolaou test in screening for and follow-up of cervical cytologic abnormalities: a systematic review. Ann Intern Med. 2000;132:810-819. [pmid: 10819705].
51 Hutchinson ML, Zahniser DJ, Sherman ME, et al. Utility of liquid-based cytology for cervical carcinoma screening: results of a population-based study conducted in a region of Costa Rica with a high incidence of cervical carcinoma. Cancer. 1999;87:48-55. [pmid: 10227593].
52 Roberts JM, Gurley AM, Thurloe JK, Bowditch R, Laverty CRA. Evaluation of the ThinPrep Pap test as an adjunct to the conventional Pap smear. Med J Aust. 1997;167:466-469. [pmid: 9397059].
53 Bolick DR, Hellman DJ. Laboratory implementation and efficacy assessment of the ThinPrep cervical cancer screening system. Acta Cytologica. 1998;42:209-213. [pmid: 9479342].
54 Chock C, Irwig L, Berry G, Glasziou P. Comparing dichotomous screening tests when individuals negative on both tests are not verified. J Clin Epidemiol. 1997;50:1211-1217. [pmid: 9393377].
55 Kaufman RH, Schreiber K, Carter T. Analysis of atypical squamous (glandular) cells of undetermined significance smears by neural network-directed review. Obstet Gynecol. 1998;91:556-560. [pmid: 9540940].
56 Jenny J, Isenegger I, Boon ME, Husain OA. Consistency of a double PAPNET scan of cervical smears. Acta Cytologica. 1997;41:82-87. [pmid: 9022731].
57 Kok MR, Boon ME, Schreiner-Kok PG, Koss LG. Cytological recognition of invasive squamous cancer of the uterine cervix: comparison of conventional light-microscopical screening and neural network-based screening. Hum Pathol. 2000;31:23-28. [pmid: 10665908].
58 Wilbur DC, Bonfiglio TA, Rutkowski MA, et al. Biopsy data confirmation. Acta Cytol. 1996;40:127-132. [pmid: 8604565].
59 Wilbur DC, Prey MU, Miller WM, Pawlick GF, Colgan TJ, Dax Taylor D. Detection of high grade squamous intraepithelial lesions and tumors using the AutoPap System: results of a primary screening clinical trial. Cancer. 1999;87:354-358. [pmid: 10603189].
60 Duggan MA. Papnet-assisted, primary screening of cervico-vaginal smears. Eur J Gynaecol Oncol. 2000;21:35-42. [pmid: 10726616].
61 Petry KU, Bohmer G, Iftner T, Flemming P, Stoll M, Schmidt RE. Human papillomavirus testing in primary screening for cervical cancer of human immunodeficiency virus-infected women, 1990-1998. Gynecol Oncol. 1999;75:427-431. [pmid: 10600301].
62 Womack SD, Chirenje ZM, Blumenthal PD, et al. Evaluation of a human papillomavirus assay in cervical screening in Zimbabwe. Br J Obstetr Gynaecol. 2000;107:33-38.
63 Womack SD, Chirenje ZM, Gaffikin L, et al. HPV-based cervical cancer screening in a population at high risk for HIV infection. Int J Cancer. 2000;85:206-210. [pmid: 10629079].
64 Wright TCJ, Denny L, Kuhn L, Pollack A, Lorincz A. HPV DNA testing of self-collected vaginal samples compared with cytologic screening to detect cervical cancer. JAMA. 2000;283:81-86. [pmid: 10632284].
65 Schiffman M, Herrero R, Hildesheim A, et al. HPV DNA testing in cervical cancer screening: results from women in a high-risk province of Costa Rica. J Am Med Assoc. 2000;283:87-93.
66 Bollen LJ, Tjong-A-Hung SP, van der Velden J, et al. Human papillomavirus deoxyribonucleic acid detection in mildly or moderately dysplastic smears: a possible method for selecting patients for colposcopy. Am J Obstet Gynecol. 1997;177:548-553. [pmid: 9322622].
67 Sigurdsson K, Arnadottir T, Snorradottir M, Benediktsdottir K, Saemundsson H. Human papillomavirus (HPV) in an Icelandic population: the role of HPV DNA testing based on hybrid capture and PCR assays among women with screen-detected abnormal pap smears. Int J Cancer. 1997;72:446-452. [pmid: 9247288].
68 Manos MM, Kinney WK, Hurley LB, et al. Identifying women with cervical neoplasia: using human papillomavirus DNA testing for equivocal Papanicolaou results. J Am Med Assoc. 1999;281:1605-1610.
69 Herrington CS, Evans MF, Hallam NFeal. Human papillomavirus status in the prediction of high-grade cervical intra-epithelial neoplasia in patient with persistent low-grade cervical cytological abnormalities. Br J Cancer. 1995;71:206-209. [pmid: 7819041].
70 Cuzick J, Sasieni P, Davies P, et al. A systematic review of the role of human papillomavirus testing within a cervical screening programme. Health Technol Assess. 1999;3:i-iv, 1-196. [pmid: 10530393].
71 Adam E, Kaufman RH, Berkova Z, Icenogle J, Reeves WC. Is human papillomavirus testing an effective triage method for detection of high-grade (grade 2 or 3) cervical intraepithelial neoplasia?. Am J Obstet Gynecol. 1998;178:1235-1244. [pmid: 9662307].
72 Hillemanns P, Kimmig R, Huttemann U, Dannecker C, Thaler CJ. Screening for cervical neoplasia by self-assessment for human papillomavirus DNA. Lancet. 1999;354. [pmid: 10622304].
73 Sun XW, Ferenczy A, Johnson D, et al. Gynecology: Evaluation of the Hybrid Capture human papillomavirus deoxyribonucleic acid detection test. Am J Obstet Gynecol. 1995;173:1432-1437. [pmid: 7503181].
74 Kavanagh AM, Broom DH. Women's understanding of abnormal cervical smear test results: a qualitative interview study. Br Med J. 1997:1388-1391.
75 Lauver D, Rubin M. Women's concerns about abnormal Papanicolaou test results. JOGNN. 1990;20:154-159. [pmid: 2030453].
76 Barsevick AM, Lauver D. Women's informational needs about coploscopy. IMAGE: J Nurs Scholarship. 1990;22:23-26.
77 Stewart DE, Lickrish GM, Sierra S, Parkin H. The effect of educational brochures on knowledge and emotional distress in women with abnormal Papanicolaou smears. Obstet Gynecol. 1993;81:280-282. [pmid: 8423964].
78 Somerset M, Peters TJ. Intervening to reduce anxiety for women with mild dyskaryosis: do we know what works and why?. J Adv Nurs. 1998;28:563-570. [pmid: 9756224].
79 Somerset M, Baxter K, Wilkinson C, Peters TJ. Mildy dyskaryotic smear results: does it matter what women know?. Int J Fam Pract. 1998;15:537-542.
80 Schofield MJ, Sanson-Fisher R, Halpin S, Redman S. Notification and follow-up of Pap test results: current practice and women's preferences. Prev Med. 1994;23:276-283. [pmid: 8078847].
81 Gustafsson L, Sparen P, Gustafsson M, Wilander E, Bergstrom R, Adami HO. Efficiency of organised and opportunistic cytological screening for cancer in situ of the cervix. Br J Cancer. 1995;72:498-505. [pmid: 7640239].
82 Mitchell H, Medley G, Higgins V. An audit of the women who died during 1994 from cancer of the cervix in Victoria, Australia. Aust N Z J Obstet Gynaecol. 1996;36:73-76. [pmid: 8775257].
83 Colgan TJ, Patten SFJr, Lee JS. A clinical trial of the AutoPap 300 QC system for quality control of cervicovaginal cytology in the clinical laboratory. Acta Cytol. 1995;39:1191-1198. [pmid: 7483997].
84 Patten SFJ, Lee JS, Wilbur DC, et al. The AutoPap 300 QC System multicenter clinical trials for use in quality control rescreening of cervical smears: II. Prospective and archival sensitivity studies. Cancer. 1997;81:343-347. [pmid: 9438459].
85 Lee JS, Kuan L, Oh S, Patten FW, Wilbur DC. A feasibility study of the AutoPap system location-guided screening. Acta Cytologica. 1998;42:221-226. [pmid: 9479344].
86 Stevens MW, Milne AJ, James KA, Brancheau D, Ellison D, Kuan L. Effectiveness of automated cervical cytology rescreening using the AutoPap 300 QC System. Diagn Cytopathol. 1997;16:505-512. [pmid: 9181316].
87 Wilbur DC, Bonfiglio TA, Rutkowski MA, et al. Sensitivity of the AutoPap 300 QC System for cervical cytologic abnormalities. Biopsy data confirmation. Acta Cytol. 1996;40:127-132. [pmid: 8604565].
88 Wilbur DC, Prey MU, Miller WM, Pawlick GF, Colgan TJ. The AutoPap system for primary screening in cervical cytology. Comparing the results of a prospective, intended-use study with routine manual practice. Acta Cytologica. 1998;42:214-220. [pmid: 9479343].
89 Wilbur DC, Prey MU, Miller WM, Pawlick GF, Colgan TJ, Dax Taylor D. Detection of high grade squamous intraepithelial lesions and tumors using the AutoPap System: results of a primary screening clinical trial. Cancer. 1999;87:354-358. [pmid: 10603189].
90 Ashfaq R, Liang Y, Saboorian MH. Evaluation of PAPNET system for rescreening of negative cervical smears. Diagn Cytopathol. 1995;13:21-36.
91 Slagel DD, Zaleski S, Cohen MB. Efficacy of automated cervical cytology screening. Diagn Cytopathol. 1995;13:26-30. [pmid: 7587871].
92 Farnsworth A, Chambers FM, Goldschmidt CS. Evaluation of the PAPNET system in a general pathology service. Med J Aust. 1996;165:429-431. [pmid: 8913244].
93 Ashfaq R, Saliger F, Solares B, et al. Evaluation of the PAPNET system for prescreening triage of cervicovaginal smears. Acta Cytol. 1997;41:1058-1064. [pmid: 9250299].
94 Duggan MA, Brasher P. Paired comparison of manual and automated Pap test screening using the PAPNET system. Diagn Cytopathol. 1997;17:248-254. [pmid: 9316778].
95 Halford JA, Wright RG, Ditchmen EJ. Quality assurance in cervical cytology screening. Comparison of rapid rescreening and the PAPNET Testing System. Acta Cytol. 1997;41:79-81. [pmid: 9022730].
96 Jenny J, Isenegger I, Boon ME, Husain OA. Consistency of a double PAPNET scan of cervical smears. Acta Cytol. 1997;41:82-87. [pmid: 9022731].
97 Kaufman RH, Schreiber K, Carter T. Analysis of atypical squamous (glandular) cells of undetermined significance smears by neural network-directed review. Obstet Gynecol. 1998;91:556-560. [pmid: 9540940].
98 Mango LJ, Valente PT. Neural-network-assisted analysis and microscopic rescreening in presumed negative cervical cytologic smears. A comparison. Acta Cytologica. 1998;42:227-232. [pmid: 9479345].
99 Mitchell H, Medley G. Detection of unsuspected abnormalities by PAPNET-assisted review. Acta Cytologica. 1998;42:260-264. [pmid: 9479349].
100 O'Leary TJ, Tellado M, Buckner SB, Ali IS, Stevens A, Ollayos CW. PAPNET-assisted rescreening of cervical smears: cost and accuracy compared with a 100% manual rescreening strategy. J Am Med Assoc. 1998;279:235-237.
101 Kok MR, Boon ME, Schreiner-Kok PG, Koss LG. Cytological recognition of invasive squamous cancer of the uterine cervix: comparison of conventional light-microscopical screening and neural network-based screening. Hum Pathol. 2000;31:23-28. [pmid: 10665908].
102 Corkill M, Knapp D, Martin J, Hutchinson ML. Specimen adequacy of ThinPrep sample preparations in a direct-to-vial study. Acta Cytologica. 1997;41:39-44. [pmid: 9022724].
103 Lee KR, Ashfaq R, Birdsong GG, Corkill ME, McIntosh KM, Inhorn SL. Comparison of conventional Papanicolaou smears and a fluid-based, thin-layer system for cervical cancer screening. Obstet Gynecol. 1997;90:278-284. [pmid: 9241308].
104 Roberts JM, Gurley AM, Thurloe JK, Bowditch R, Laverty CR. Evaluation of the ThinPrep Pap test as an adjunct to the conventional Pap smear. Med J Aust. 1997;167:466-469. [pmid: 9397059].
105 Bolick DR, Hellman DJ. Laboratory implementation and efficacy assessment of the ThinPrep cervical cancer screening system. Acta Cytol. 1998;42:209-213. [pmid: 9479342].
106 Inhorn SL, Linder J, Wilbur DC, Zahniser D. Diagnosis of invasive cervical carcinoma with fluid-based, thin-layer slide preparation method. Prim. Care Update Ob Gyns. 1998;5. [pmid: 10838307].
107 Papillo JL, Zarka MA, St John TL. Evaluation of the ThinPrep Pap test in clinical practice. A seven-month, 16,314-case experience in northern Vermont. Acta Cytologica. 1998;42:203-208. [pmid: 9479341].
108 Sherman ME, Mendoza M, Lee KR, et al. Performance of liquid-based, thin-layer cervical cytology: correlation with reference diagnoses and human papillomavirus testing. Modern Pathol. 1998;11:837-843.
109 Hutchinson ML, Zahniser DJ, Sherman ME, et al. Utility of liquid-based cytology for cervical carcinoma screening: results of a population-based study conducted in a region of Costa Rica with a high incidence of cervical carcinoma. Cancer. 1999;87:48-55. [pmid: 10227593].