# Results

This chapter presents the results of our systematic review on three main issues: screening among women who are 65 years of age and older or who have had a hysterectomy, technologies for cervical cytology, and testing the human papilloma virus (HPV) as a part of cervical cancer screening. Evidence Tables detailing information from the literature examined by members of the RTI-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) can be found in Appendix C.

## Key Question 1

### Screening Among Women Age 65 and Older

Twelve articles since 1995 provided sufficiently detailed information about results of screening by age to examine the evidence about screening among older women (Evidence Table 1A, Appendix C). For inclusion, we required that the study include women above age 50, that data be presented stratified by age or in subanalyses that compared older to younger women, and that the denominators for the outcomes be known (e.g., the number of abnormal Pap results reported corresponds to a defined number of individual women screened or number of Pap tests obtained in a specified group of women). The majority of rejected studies were ecologic-level reports correlating population-based rates of detection of dysplasia and/or cancer with Pap testing trends, or case-control studies that matched on age and contributed only to the literature about interval, or models validated using data that would not meet the inclusion criteria.

In toto, the included studies tell different versions of the same story about the influence of age on risk for high-grade cervical lesions and cancer:

- Incidence of cervical intraepithelial neoplasia (CIN), including CIN 3 and carcinoma in situ (CIS), peaks in the mid-reproductive years and begins to decline in approximately the fourth decade of life.^26,34-36^
- The prevalence of CIN follows a similar pattern: diagnosis of CIN 3 and CIS is shifted toward older age at diagnosis relative to CIN 1 and 2 but still decreases with age.^37-40^
- This general pattern is also apparent among previously unscreened women.^40,41^
- Based on the incidence of cancers that arise between screening intervals, cervical cancer in older women is not more aggressive or rapidly progressive than that in younger women.^ 42 ^
- The rates of high-grade squamous intraepithelial lesions (HSIL) diagnosed by cytology are low among older women who have been screened: 0.2-1.9,^ 36 ^ 0.7-1.7,^ 40 ^ and 0.8-1.4,^ 26 ^ per 1,000 among women ages 50 years and older.

These observations are consistent with ecologic data and natural history studies of cervical dysplasia and cancer and studies of HPV progression. Three of the included studies rely only on cytology results.^26,36,37^ The remainder have varying degrees of histologic documentation; these range from complete or near complete histologic documentation of all cases,^38,40-44^ to good verification of cases (72% verified^ 39 ^ to 82% verified^ 35 ^) to inadequately described use of histologic "gold standard."^ 34 ^ None attempted to identify false negatives through evaluation of women with negative screening tests. As such, this literature reflects the quality of the cytology services deployed to screen the retrospective and prospective cohorts that make up the study populations. Relative comparisons of the effectiveness of the screening systems and of the potential impact of screening interval cannot be made across studies.

With these caveats, we describe in greater detail selected studies of incidence of histologic or cytologic abnormalities among previously screened women, prevalence within screening programs, and the influence of interval and prior screening history on probability of detecting abnormalities.

#### Incidence and Age

Each of the studies reporting incidence of CIN and more serious lesions constructed their cohort by requiring a normal Pap test as the earliest reference point. Computerized record-keeping systems from a single cytology laboratory^34,35^ assure relative consistency of quality of examination of the baseline and subsequent Pap tests; in relatively stable populations, they also allow exclusion of women with prior documentation of abnormal cytology. Sawaya and colleagues prospectively gathered data assuring that baseline cytology for individuals entering the study was reported as normal; however, this does not exclude the possibility that participants may have had a more remote history of dysplasia evaluation or treatment.^26,36,44^ In the reports based on the National Breast and Cervical Cancer Early Detection Program, laboratory facilities across the United States processed Pap tests;^26,36^ in the Heart and Estrogen/progestin Replacement Study (HERS) study, a single commercial laboratory (Empire Pathology Medical Group, Garden Grove, CA) processed tests.^ 44 ^

Despite these distinctions and different groupings of age in the analysis of data, estimates of incidence of high-grade lesions are compatible across the studies of incidence: 1.0 per 1,000 women 41 years of age and older, screened at an interval of approximately 1 year;^ 34 ^ 1.2 per 1,000 person-years among women 40 years of age and older;^ 35 ^ 1.4 per 1,000 women ages 50 to 64 years and 0.8 per 1,000 women 65 and older screened at an interval of 36 months or less;^ 26 ^ 0.6 to 1.9 per 1,000 smears in women ages 50 to 59 years; 0.2 to 1.2 in women 60 or older;^ 36 ^ and 0.4 per 1,000 women in a post-menopausal cohort with average age of 66.^ 44 ^ Fewer than one woman in a thousand (in some studies as few as two to six in 10,000) who were age 60 and older and had a negative smear at baseline received a new diagnosis of CIN 3 or cancer. In studies that had cases of cancer in screened populations of older women, the ratio of CIN 3 to cancer range from 4 to 1^ 26 ^ to more than 10 to 1.^ 40 ^

#### Prevalence

Studies of prevalence (i.e., those that include screened and unscreened women without requirement of baseline normal cytology) are also compatible with the assertion that risk of high-grade cervical abnormalities decreases with age. The only study that does not appear to support this view is that of Formso and colleagues;^ 37 ^ they report 2.23 cytologic findings of CIN 3 per 1,000 women age 50 to 59 years; 1.96 per 1,000 for women age 60 to 69 years; and 4.24 for women ages 70 and older. The inclusion criteria specified "no prior abnormal Pap test"; this allowed inclusion of women having their first screening ever or after an extended interval. In the text, the authors noted the large proportion of older women, especially those older than 70, who had first Pap tests included in these data. Their data are based on records from the same cytology laboratory in Norway used by Gram et al.^ 35 ^ The laboratory serves a relatively stable population in two northern counties without a formal screening program. The time periods in the analyses by Formso et al.^ 37 ^ and Gram et al.^ 35 ^ overlap by two years; thus, presumably individual-level data may be duplicated in these reports. Gram and colleagues sought histologic confirmation of CIN 3 and carcinoma and achieved an 82% verification rate, whereas Formso and colleagues relied on cytology alone. The differences between their findings are certain to reflect the inclusion of unscreened women in the prevalence study^ 37 ^ but not in the incidence study.^ 35 ^ The differences may also reflect discrepancies between cytology and histology among older women and unstable estimates based on small numbers.

The remaining publications reflect falling risk with age and low prevalence among older women. These include the Cecchini et al. study of previously unscreened women in Italy,^ 41 ^ Cruickshank's study^ 39 ^ among British women who are actively advised to be screened every 3 years, and the work by Lawson and colleagues based on opportunistic screening in the US National Breast and Cervical Cancer Screening Program.^ 40 ^ Among American women being screened for the first time in the study by Lawson et al.,^ 40 ^ rates of CIN 3 or cancer were 2.3 per 1,000 Pap tests among women ages 50 to 64 and 1.7 per 1,000 among those ages 65 and over, followed by a reduction to 1.3 per 1,000 and 0.7 per 1,000 at the second screening opportunity.

#### Screening History and Interval

The significance of prior negative smears is directly addressed by both age-adjusted and age-specific analyses in the examination by Sawaya and colleagues of the probability of abnormal Pap after 1, 2, or 3 prior normal Paps. The probability of HSIL decreases with each subsequent normal smear in women ages 30 and older. Reduction within age brackets is detailed in Evidence Table 1. Investigation of the influence of interval suggests that longer intervals are associated with similar or increased detection of high-grade lesions;^26,35,43^ other work not reviewed here (but considered by the US Preventive Services Task Force [USPSTF] in the mid-1990s) suggests that cancer outcomes are statistically comparable with intervals of three to five years. Three years was recommended as a conservative estimate of appropriate interval.

### Screening among Women Who Have Had a Hysterectomy

The 1996 USPSTF report is unequivocal: "women who have undergone a hysterectomy in which the cervix was removed do not benefit from Pap testing, unless it [the hysterectomy] was performed because of cervical cancer."(p.111)^ 4 ^ This opinion was based on recognition that Pap testing in the absence of a cervix no longer constitutes screening for cervical cancer. In this context the Pap test becomes screening for vaginal cancer, a yet more rare condition. Prior publications support this view.^ 45 ^ Nonetheless, a recent publication based on practice patterns at the Marshfield Clinic (a 450-physician multi-specialty clinic in Wisconsin) suggests that more than half of women who have had total hysterectomies for benign disease continue to receive screening at an average of one test every 3.5 years.^ 46 ^ This confirms the clinical opinion of members of our group that the majority of women continue to receive screening even after hysterectomy for benign disease.

Two additional studies documenting the low risk of cytologic abnormality after hysterectomy have been published since the 1996 USPSTF recommendations. The first, among women age 50 and older, is a cross-sectional study with a nested case-control component.^ 47 ^ They documented that identification of dysplasia and cancer was rare (1.6/1,000 tests) in this age group, especially after hysterectomy (0.18/1,000). They also showed that, compared to matched controls, women after hysterectomy were one tenth as likely as those with a cervix to have any Pap test diagnosis of abnormality.^ 47 ^ Likewise, Pearce and colleagues' study of 6,265 women (with 9,610 Pap tests) who had hysterectomies for benign disease found a total of 104 abnormal Pap test from 79 women within a two-year timeframe.^ 48 ^ At completion of follow-up, 3 women had vaginal intraepithelial neoplasia (VAIN) and one had squamous cell carcinoma. This translates into 0.42 high-grade lesions per 1,000 Pap tests.^ 48 ^ These articles are described in greater detail in Evidence Table 1B.

### Summary

The available evidence about age and screening outcomes is observational, from large population-based retrospective cohorts supported by registry systems, or from smaller prospective cohort studies. Despite varied study design and populations, the findings are coherent and support the assessment that risk of high-grade cervical lesions falls with age, especially among those with prior normal screening results. Because none of these studies evaluates outcomes among women who did not receive further screening after a designated age, and because none is experimental, we cannot draw direct conclusions about the anticipated results of discontinuing screening at a specific age.

Prior USPSTF recommendations to discontinue Pap testing after hysterectomy for benign disease are supported by a well-conducted study; they should be re-emphasized. Lastly, no direct comparisons between proposed screening systems, including those based on individual risk assessment, were identified. This confirms that this literature is substantially less well-developed than that of other areas of screening tests, such as colorectal cancer screening in which trials comparing annual fecal occult blood testing to sigmoidoscopy are available to inform decisionmaking.

## Key Question 2

### New Methods for Preparing or Evaluating Cervical Cytology

Key Question 2 (To what extent do new methods for preparing or evaluating cervical cytology improve diagnostic yield compared to conventional methods?) is addressed predominantly by direct comparisons of diagnostic tests. The majority of the literature identified for Key Question 2 is based on archived laboratory specimens. These studies compare the techniques being evaluated with the results of review by a panel of cytology experts. Most often, these comparisons are conducted by subjecting specimens with a pre-selected mix of normal and abnormal cytologic results, to review by the techniques under study. In general, discrepancies between cytology reports were adjudicated by the expert panel masked to findings; rarely, subsets of normal or concordant diagnoses were also reviewed by the panel.

Very few studies of new technologies are validated by concurrent or subsequent colposcopy or histology of abnormal screening test results; even fewer include validation of normal screening test results. This means that in almost all studies identified the sensitivity, specificity, and predictive values of the technology cannot be directly assessed or compared with the test characteristics of conventional cytology in the same population.

Our search identified 196 articles on the types of technology we wished to review. We excluded 143 of these articles at the time of abstract review because they did not meet basic inclusion criteria (e.g., were commentaries, were based on experimental laboratory systems, did not have human subjects). Forty-eight full articles were retrieved; these included 23 that were found not to meet basic inclusion criteria (commentary and reviews). Of the remaining 25 articles, four were relevant new articles not previously abstracted and summarized in the AHCPR Evidence Report/Technology Assessment, Number 5: Evaluation of Cervical Cytology; two were new articles on screening tools not covered by either systematic review (e.g., unaided visual inspection of the cervix, and cervicography); and one article was a final publication of a study that had been reviewed in draft form for Cervical Cytology report and had minor changes in the final published results.^ 49 ^

The Cervical Cytology report was published in February 1999^ 32 ^ and updated in January 2000 for peer-reviewed publication.^ 50 ^ The report includes studies with and without validation of screening tests by clinical evaluation. For convenience, the portions of the evidence tables from that report that are related to new technologies are reproduced and updated in this report (Evidence Table 2). In collaboration with the authors of the cervical cytology report, the RTI-UNC EPC team abstracted new articles in a comparable fashion.

As described in the methods section, we had planned to focus on studies that used colposcopy or histology as a gold standard for evaluation of performance of the screening system. However, such publications remain rare. At completion, we extended the prior Cervical Cytology review by updating final data from one article, adding three new articles based on a cytological reference standard with or without a subset of histologic verification, and adding one with an adequate colposcopic and histologic reference standard. This study applied a definitive clinical reference standard to a random sample of women with normal screening test results and permitted calculation of all test characteristics including estimation of specificity.^ 51 ^

Evidence Table 2 (Appendix C) summarizes 29 studies that evaluate the performance of new technologies for preparing or interpreting cervical cytology specimens: 9 evaluating liquid-based cytology collection systems (ThinPrep^®^); 13, neural-net rescreening or prescreening studies (PapNet^®^), and 7, computer algorithms for selecting slides for rescreening or for screening (AutoPap^®^).

A single study evaluating ThinPrep^®^ liquid-based cytology and other screening modalities in a population-based cohort of 8,636 Costa Rican women met strict review criteria for prospective evaluation of the test characteristics of a new screening technology:^ 51 ^

1. Cytology specimen obtained as a screening study;
2. Performance of new technology was evaluated by colposcopy and/or histology as the reference standard;
3. Pap and reference standard were applied within an average of three months; and
4. A validation of normal cytology results was undertaken, such that a complete 2x2 table relating the new technology to the reference standard can be completed.

The study that met these criteria used colposcopy and histology to evaluate women in three categories: (1) atypical squamous cells of uncertain significance (ASCUS) on cytology as assessed by ThinPrep, PapNet, or conventional smear; (2) positive cervigram; or (3) physical examination suspicious for cancer or gynecologic emergency (rare indication). These investigators conducted a validation substudy among a random sample of 150 women with negative screening results, thus allowing estimation of specificity and predictive values. Their reference standard was a composite of all screening tests and histology findings, called the final case diagnosis. The final case diagnosis categories were negative (including ASCUS with normal colposcopy and/or histology), low-grade squamous intraepithelial lesion (LSIL) (by histology, or by cytologic confirmation by two or more methods), HSIL (93% histologic confirmation), invasive carcinoma (100% histologic confirmation), and equivocal. Equivocal included women with a single cytologic diagnosis of LSIL, isolated positive cervigram, or conflicting results on the basis of all the data. Because the threshold for colposcopy was ASCUS or higher, the majority of equivocal final case diagnoses are presumed to be equivocal low-grade findings although the precise make-up of this group is not clearly specified in the article.

Bearing this classification system in mind, we have calculated performance measures for ThinPrep^®^ using two different assumptions about equivocal final diagnosis; one assumption includes them in normal, and the other in LSIL. Based on the findings of no abnormal histology among the random sample of 150 women with normal final diagnoses (i.e., all screening test negative) who were evaluated with colposcopy and biopsy, estimates of sensitivity, specificity and predictive value are based on the presumption of no false negatives, which is plausible based on the number of tests applied and the consensus process for assigning the final diagnoses. Table 6 summarizes test characteristics at different thresholds; assignment of the equivocal cases is indicated.

Table 6. Performance of ThinPrep® in a Prospective Cohort*

ThinPrep Cytology Threshold | Final Diagnosis | Number with Diagnosis (%) | "Equivocal"^†^ | Actual Sens^‡^ (%) | Estimated
ThinPrep Cytology Threshold | Final Diagnosis | Number with Diagnosis (%) | "Equivocal"^†^ | Actual Sens^‡^ (%) | Spec (%) | PPV^\|\|^ (%) | NPV (%) | +LR^#^ | -LR**
> ASCUS^††^ | > LSIL^‡‡^ | 323 (3.7) | With Normal | 87.9 | 90.5 | 95.9 | 99.5 | 9.3 | 0.13
> ASCUS | > LSIL | 1019 (11.8) | With LSIL | 55.4 | 93.0 | 51.6 | 94.0 | 7.9 | 0.48
> LSIL | > LSIL | 323 (3.7) | With Normal | 79.6 | 97.7 | 57.8 | 99.2 | 34.6 | 0.21
> LSIL | > LSIL | 1019 (11.8) | With LSIL | 42.7 | 99.9 | 97.8 | 92.9 | 42.7 | 0.57
> HSIL | > HSIL | 137 (1.6) | With < HSIL | 67.2 | 99.3 | 61.3 | 99.5 | 98.4 | 0.33
> LSIL | > HSIL | 137 (1.6) | With < HSIL | 89.8 | 96.1 | 25.8 | 99.8 | 23.1 | 0.11

*Data summarized from Hutchinson et al., 1999.^ 51 ^

†Category in which final case diagnoses of "equivocal" were assigned for the calculation of test characteristics of ThinPrep; 696 of 8,636 subjects (8.1%) had a final diagnosis of equivocal "conferred...with various combinations of results, including a single cytologic diagnosis of LSIL by any method, and isolated positive cervigram, or equivocal results based on the review of all available data."^ 51 ^ (50)

‡ Sens, sensitivity

§ Spec, specificity

|| PPV, positive predictive value

¶ NPV, negative predictive value

# +LR, positive likelihood ratio;

** -LR, negative likelihood ratio.

†† ASCUS, atypical squamous cells of uncertain significance

‡‡ LSIL, low-grade squamous intraepithelial lesion

§§ HSIL, high-grade squamous intraepithelial lesion

Two studies of ThinPrep^®^, known for the large size of the populations screened (>35,000 each), did not meet strict criteria. These studies provide histology results for a subset of subjects obtained within undisclosed periods of time from the screening ThinPrep^®^.^52,53^ Neither used a colposcopy/histology reference standard to verify test negatives, and both studies appear to rely on histology specimens associated with clinical care for calculating sensitivity and specificity of the ThinPrep^®^ test compared to conventional cytology.

Among 10,694 US patients in the latter study screened by ThinPrep^®^, 630 women had cytology diagnoses of ASCUS or more severe; 1,395 of 39,408 women screened by conventional cytology had cytology of ASCUS or more severe.^ 53 ^ However, the estimates of sensitivity and specificity reported in the publication are based on 54 biopsy reports in the ThinPrep^®^ group and 89 in the conventional cytology group. The authors do not specify how these "available" biopsies were identified. They could not capture those women who had normal colposcopy, and therefore no biopsy, among those with abnormal cytology. Additionally, ThinPrep^®^ and conventional specimens were from separate groups of women, not one of each specimen type from each individual. As a result, the sensitivity and specificity of ThinPrep^®^ (reported as 95% and 58%, respectively) are not valid and cannot be appropriately compared with conventional cytology (reported as 85% and 36%).

The earlier study obtained split samples for ThinPrep^®^ and conventional cytology from a cohort of 35,560 Australian women.^ 52 ^ Within the Australian health care system, colposcopy is the recommended immediate evaluation for "inconclusive" slides in which high-grade abnormalities cannot be excluded and for cytology diagnoses of CIN1 and above. High-grade or inconclusive cytology results were reported for 433 ThinPrep^®^ specimens and 430 conventional cytology specimens, of these, 325 (75%) and 319 (74%), respectively, had histology results. This again excludes women who had colposcopy without biopsy. However, the focus on high-grade lesions makes the probability of biopsy high, and so the proportion with follow-up is adequate. In this context, the relative true-positive and false-positive rates of the test can be used to compare performance.^ 54 ^ The relative true-positive rate for ThinPrep^®^ compared to conventional cytology for detecting high-grade histologic abnormalities is 1.13, suggesting a modestly higher sensitivity of Thin Prep^®^; the relative false-positive rate is 1.12, suggesting a modestly lower specificity.

#### Neural-network Rescreening

The literature about neural-network rescreening (and screening) technology is also fundamentally limited by the lack of histologically confirmed performance measures. Applying the same criteria outlined above, we found no studies that met the inclusion standards. One study of 160 slides originally classified by conventional cytology as ASCUS and subsequently scanned by the PapNet^®^ system is supported by histology for all samples.^ 55 ^ This study failed to meet criteria because the reference standard was obtained up to one year after the screening test and because the slides reviewed do not reflect a representative distribution of normal and abnormal specimens. We summarize this work and two other studies with some use of histology documentation as examples of the content of the literature.

The slides for this ASCUS review study, selected because the patients had subsequent histology on record, were re-read using PapNet^®^. Although the spectrum of disease is skewed and reflects a high prevalence of abnormalities, performance measures can be calculated for LSIL and HSIL given an initial ASCUS determination by conventional Pap. If histology of HPV changes only is separated from CIN 1 and included with normals, the sensitivity, specificity, positive predictive value, and negative predictive value of PapNet^®^ categorization of LSIL or greater are 45.4%, 85.8%, 45.5%, and 85.8%, respectively. If HPV changes are included in CIN, these values are, respectively, 37.7%, 92.3%, 78.8%, and 66.1%. At a PapNet^®^ threshold of HSIL or greater for detecting CIN 2, CIN 3, or carcinoma, the sensitivity was 27.3%, specificity was 94.2%, positive predictive value, 42.9%, and negative predictive value, 89.0%.

Jenny and colleagues hand-selected a slide set consisting of 516 abnormal slides with accompanying histologic record of abnormality and mixed them with 684 slides from women with 2 years of normal follow-up.^ 56 ^ The study was designed to evaluate the consistency of reports between two independent PapNet^®^ evaluations and a manual screening of the same slide set. The PapNet^®^ evaluations identified 91% and 84% of the histologically proven abnormal specimens; conventional screening classified 78% as abnormal. The resulting true positive ratio of PapNet^®^ to conventional screening ranges from 1.08 to 1.16, supporting the claims that PapNet^®^ reduces false negatives. Unfortunately, the research team missed the opportunity to evaluate all performance measures using the 2-year normal follow-up group as a fairly well-documented confirmation of test negatives. The authors do not comment on the classification of the normal slides, focusing only on the 516 slides from women with known abnormalities.

Using data from the centralized Dutch national pathology reporting program, Kok and colleagues evaluated cervical cancer outcomes and risk of screening method failure in 2 large groups: 109,104 smears evaluated by conventional screening and 245,527 slides submitted for neural-network based screening (not rescreening as in the United States) with PapNet^®^.^ 57 ^ They used the reporting system to identify 71 women with a diagnosis of biopsy-confirmed squamous cell carcinoma and to locate the screening smear obtained prior to the biopsy. Of the 71 smears, 19 had been evaluated by conventional methods and 52 by PapNet^®^ screening; there were four false negatives among the conventional screening group and five false negatives among the PapNet^®^ slides. The balance of the 71 smears were all reported with a level of abnormality ranging from LSIL to carcinoma that prompted clinical follow-up. The false negatives were subjected to masked detailed review by both standard microscopy and PapNet^®^. All five PapNet^®^ failures were confirmed to be sampling errors; i.e., the slides did not contain identifiable abnormal cells as assessed by hand review or PapNet^®^. The conventional screening failures did contain scant abnormal cells and constitute screening failures. Two independent, masked PapNet^®^ re-evaluations of the slides classified three of the four as "suspicious" and the fourth as CIN 3, suggesting that the screening failures could have been averted because none of these individuals would otherwise have been returned to the 5-year routine screening interval.

#### Computerized Rescreening

AutoPap^®^ is a computerized quality control system that can be used for initial screening and for optimizing selection of high-risk slides for rescreening. Its current routine use in the United States is restricted to rescreening. We found no studies that met strict criteria for review, although we did identify two studies by the same group that employed a level of histologic verification of test performance. The first was based on an 86-slide set of smears from histology-proven HSIL cases.^ 58 ^ This study retrospectively measured whether the system "found" these slides when they were reviewed as part of a larger study. The system can be set to determine the proportion of slides that will be rescreened; this study evaluated 10-percent and 20%- rescreening thresholds. At the 10%- review threshold, AutoPap selected 77% of the HSIL slides for assessment; at the 20%- threshold, it selected 86% for assessment. These figures are substantially higher than the expected maximum selection rate of 10% of false negatives if the standard random sample of 10% of negative slides were to be used to determine rescreening.

In a subsequent study, this group focused on ability of the AutoPap^®^ system to aid identification of HSIL lesions.^ 59 ^ This cytologic diagnosis should consistently be associated with clinical evaluation and histology, which improved their ability to confirm positive diagnoses although again they have no verification of the test-negative specimens. Within a parent study with 25,124 screened slides, they identified 70 slides supported by definitive diagnoses of HSIL, CIS, or invasive cancer. They compared the detection rate for these slides in the convention practice screening and the AutoPap^®^ screening portion of the parent study. Both modalities detected 63 of 70 abnormal slides; conventional practice failed to detect five and AutoPap^®^ failed to detect two. The performance of the two modalities was statistically equivalent.

Although we updated the evidence tables from the Cervical Cytology report by including two new studies about PapNet^57,60^ and a final publication of an article available in manuscript form,^ 49 ^ we have not summarized them in greater detail here. The reason is that these reports use cytology reference standards and do not change the overall picture of the performance of new technologies. Thus, they serve as confirmation of similar earlier publications, not as wholly new information.

#### Harms

We did not identify publications that specifically address harms of new technologies for cervical cancer screening. These screening tools are implemented at the laboratory level and not at the level of clinical specimen collection, so they do not increase risk of harm from the actual specimen acquisition.

The performance characteristics of the new technologies will determine the risk of harm. Although the data are limited, on average these tools improve sensitivity and reduce specificity. This finding suggests that increased detection of low-grade lesions and false positives are the primary potential sources of harm; i.e., harm may take the form of increased evaluations, possible over-intervention, and psychological distress for the women diagnosed with abnormalities. These harms are poorly documented for conventional Pap testing and have not yet been assessed for new technologies.

#### Benefits

Likewise, direct benefits of new technologies for improving care processes or outcomes are not documented. The characteristics of these new tools suggest that they can improve detection of precancerous lesions when compared in a single screening session to conventionally prepared and interpreted cytology. However, no data are available to assess their long-term benefit if implemented in a screening system. Cervical dysplasia is at times a spontaneously resolving condition or, if progressive, a slowly developing condition. For precisely these reasons, the full system of screening-i.e., the modality used, the interval for testing, and the decisionmaking process related to evaluation and treatment-need to be evaluated in toto to compare performance characteristics properly. Prospective measurement of outcomes is essential to guiding policy.

#### Costs

A central goal of the Evaluation of Cervical Cytology evidence report was modeling the effects on total health care costs, morbidity, and mortality of regular cervical cytologic screening using newer screening technologies compared with conventional Pap smear in women participating in screening.^ 32 ^ Using a Markov model of a cohort of women ages 15 to 85, incorporating estimates about the natural history of HPV, and investigating one-, two-, and three-year screening intervals, they reached the following conclusions:

- The cost-effectiveness of either a technology that improves primary screening sensitivity (e.g., thin-layer cytology) or one that improves rescreening sensitivity (e.g., computerized rescreening) is directly related to the frequency of screening-longer intervals result in lower estimates of cost per life year saved.
- Findings were relatively insensitive to assumptions about cervical cancer incidence, cost of technologies, diagnostic strategies for abnormal screening results, age at onset of screening, or most of the other variables tested.
- Substantial uncertainty surrounds the estimates of sensitivity and specificity of thin-layer cytology and computerized rescreening technologies compared with each other and with conventional Pap testing. This uncertainty is not reflected in the point estimates of cost-effectiveness. Although both thin-layer cytology and computerized rescreening technologies clearly improve effectiveness at higher cost, the imprecision in estimates of effectiveness makes drawing conclusions about the relative cost-effectiveness of thin-layer cytology and computerized rescreening technologies problematic.
- Given the uncertainty surrounding these estimates, all three technologies may well fall within accepted ranges of cost-effectiveness at 3-year screening intervals. No strategy or technology used for screening more often than every 3 years results in estimates of less than $50,000 per life-year.

This model substantially improves on prior work; it includes global costs of downstream care resulting from screening and cancers, more accurate estimates of the performance of conventional cytology then previously available, and sophisticated sensitivity analyses. However, important parameters of this model deserve note. Base assumptions include the following: (1) all women receive screening at the appropriate interval; (2) new technologies increase sensitivity without any decrement in specificity; (3) all patients receive appropriate follow-up; and (4) diagnostic evaluation of abnormal cytology detects all true abnormalities (i.e., no colposcopy or pathology errors are made). Adjusting each of these assumptions closer to actual clinical scenarios has the effect of increasing the cost-effectiveness ratio. If, as our update and the full Cervical Cytology report suggest, new technologies do have lower specificity than conventional cytology, then costs and harms of false positives have important system and individual implications.

The Cervical Cytology report also includes systematic review of prior literature on the cost-effectiveness of cervical cytology. In summary:

- Published models examining the cost and effectiveness of Pap smear screening have consistently found Pap screening to have a significant impact on the incidence and mortality of cervical cancer and to have an acceptable range of cost-effectiveness ratios when compared with no screening.
- Estimates of Pap test accuracy used in these models generally overestimated Pap test performance, as determined by recent unbiased studies, the findings of the report itself [Cervical Cytology], and a previously published meta-analysis. Best estimates of Pap test performance fall outside the range used in sensitivity analyses of some models.

Many of these models have results that are consistent when important parameters of the models are varied across of broad spectrum of assumptions. Ultimately, however, all current models are tied to the limitations in this literature and must be considered temporary substitutes for prospective research.

#### Summary

Overall, the quality of this literature is limited for the purposes of making decisions about choice of screening modality in the US population. We identified no randomized trials or prospective cost-effectiveness comparisons in suitable populations. In the absence of studies that relate the findings at screening to outcomes, the linkages between comparative test performance are insufficient to judge the implications of preferentially using one system over another.

## Key Question 3: Role of HPV Testing in Cervical Cancer Screening

We examined two potential roles for HPV testing in cervical cancer screening. The first is focused on screening use of HPV testing, including simultaneous use with Pap testing. The second envisions a role for HPV in triaging women with abnormal screening Pap results with an emphasis on when knowledge of HPV status might modify decision-making about the need for or extent of further evaluation. Our specific questions were:

3A. Screening Use of HPV Testing: What are the benefits, harms, and costs of using HPV testing as a screening test, or of incorporating HPV testing at the time of the screening Pap test compared with not testing for HPV? 3B. Triage Use of HPV Testing: What are the benefits, harms, and costs of using HPV testing as part of a screening strategy to determine which women with an abnormal Pap test should receive further evaluation?

We reviewed 30 potentially relevant publications. Ultimately, we abstracted 13 of these and entered their data into Evidence Tables 3A and 3B; we retained another three articles for background. The systematic review of the role of HPV testing in cervical cancer screening prepared by Cuzick and colleagues for the UK Health Technology Assessment Board of the National Health Service was a valuable aid.^ 21 ^ Their publication influenced our decisionmaking about which testing modalities to consider appropriate for screening use, and it validated the literature search strategy we used for this SER by confirming that we were identifying appropriate publications.

### Screening Use of HPV Testing

Six studies relevant to primary screening uses of HPV testing met four strict criteria for inclusion:

1. HPV specimen obtained and evaluated as a screening test;
2. Performance of HPV for predicting presence of CIN was evaluated by colposcopy and/or histology as the reference standard;
3. HPV test and reference standard were applied within an average of 3 months; and
4. A validation of negative HPV results was undertaken, such that a complete 2x2 table relating the HPV test findings to the reference standard can be completed.

These articles are summarized in detail in Evidence Table 3A. Table 7 extracts key features of all 6 studies and their populations to demonstrate the varied spectrum of disease in the populations screened. Although each of these studies used HPV testing in a population or clinic-based sample that enrolled consecutive women in a fashion comparable to screening use, 5 of the 6 studies used a study population at high risk for cervical dysplasia. One obtained specimens from HIV-positive German women;^ 61 ^ 2 were based in Zimbabwe and enrolled primary care patients in a population chosen for high prevalence of HIV infection;^62,63^ 1 selected participants in Cape Town, South Africa, with no prior screening;^ 64 ^ and 1 enrolled women from Guanacaste Province, Costa Rica, where cervical cancer screening has been relatively unsuccessful in reducing cervical cancer incidence.^ 65 ^ Only Cuzick and colleagues' study of 2,988 women having routine cervical cancer screening at 40 general practitioner practices approximates screening use in routine primary care practice in the United States.^ 21 ^

Table 7. Studies with Screening Uses of HPV* Testing

Article | Population | Prevalence of LSIL^†^ (%) | Prevalence of HSIL^‡^ (%) | Prevalence of Carcinoma (%)
Cuzick et al., 1999^ 21 ^ | 2,988 women age > 34 presenting for routine Pap screening in UK | HPV/borderline = 1.9; CIN 1 = 0.9 | CIN 2 = 0.3 CIN 3 = 1.1 | No cases
Petry et al., 1999^ 61 ^ | 138 HIV infected women | CIN 1 = 14.5 | CIN 2 = 3.6 CIN 3 = 6.5 | Invasive Ca^\|\|^ = 2.2
Schiffman et al., 2000^ 65 ^ | 8,554 Costa Rican women from random door-to-door selection | Equivocal = 7.7; LSIL = 2.2 | HSIL = 1.5 | Invasive Ca^\|\|^ = 0.14
Womack et al., 2000^ 63 ^ | 466 women age 25-55 in primary care clinics in Zimbabwe | LSIL = 12.9 | HSIL = 12.0 | No cases
Womack et al., 2000^ 62 ^ | 2,140 women age 25-55 in primary care clinics in Zimbabwe | LSIL = 16.2 | HSIL = 10.0 | Invasive Ca^\|\|^ = 0.14
Wright et al., 2000^ 64 ^ | 1,365 unscreened women, age > 35 from clinics in South Africa | LSIL = 2.9 | HSIL = 3.4 | Invasive Ca^\|\|^ = 0.7

* HPV, human papilloma virus.

^†^ LSIL, low-grade squamous intraepithelial lesion.

^‡^ HSIL, high-grade squamous intraepithelial lesion.

CIN, cervical intraepithelial neoplasia.

^||^ Invasive Ca, invasive cancer.

HPV types consistently considered high risk and tested by the assays used in these studies included types 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, and 68. We have not considered performance characteristics of tests that detect only low-risk HPV types. Basic performance characteristics relating presence of high-risk HPV types to diagnoses are best summarized by considering HSIL and LSIL as separate diagnostic thresholds. For the HSIL threshold, we mean the ability of a positive HPV test to detect histology-proven HSIL or more severe lesions, such as invasive cancer. For the LSIL threshold, we mean the ability of a positive HPV test to detect histology-proven LSIL or more severe lesions, including HSIL.

#### HPV Screening for Detection of High-grade Cervical Changes

The sensitivity of a positive Hybrid Capture II test for high-risk HPV types for detecting histology proven HSIL or greater ranged from 62% to 95%.^21,62-65^ Specificity ranged from 41% to 94%.^21,62-65^ Details of test performance for detecting high-grade lesions, including predictive values and likelihood ratios for positive and negative tests, for each HPV test modality examined in these screening-based studies appear in Table 8.

Table 8. Performance of Screening HPV* Testing for Detection of High-grade Abnormalities

Article | Test Method | Total N | True Positive | False Neg | Sens^†^ | True Neg | False Positive | Spec^‡^ | Prev | PPV^\|\|^ | NPV^\|\|^ | Pos LR | Neg LR
Cuzick et al., 1999^ 21 ^ | SHARP^#^ | 2988 | 31 | 11 | 73.8 | 2801 | 145 | 95.1 | 1.4 | 17.6 | 99.6 | 15.0 | 0.3
| HC I** | 1285 | 11 | 5 | 68.8 | 1024 | 245 | 80.7 | 1.3 | 4.3 | 99.5 | 3.6 | 0.4
| HC II | 1703 | 20 | 1 | 95.2 | 1586 | 96 | 94.3 | 1.2 | 17.2 | 99.9 | 16.7 | 0.1
Petry et al., 1999^ 61 ^ | HC I (HIV+^††^) | 138 | 16 | 1 | 94.1 | 97 | 24 | 80.2 | 12.3 | 40.0 | 99.0 | 4.7 | 0.1
Shiffman et al., 2000^ 65 ^ | HC I | 8554 | 104 | 35 | 74.8 | 7859 | 556 | 93.4 | 1.6 | 15.8 | 99.6 | 11.3 | 0.3
| HC II | 1119 | 122 | 16 | 88.4 | 873 | 108 | 89.0 | 12.3 | 53.0 | 98.2 | 8.0 | 0.1
Womack et al., 2000^ 63 ^ | HC II (HIV +^††^) | 249 | 39 | 4 | 90.7 | 85 | 121 | 41.3 | 17.3 | 24.4 | 95.5 | 1.5 | 0.2
| HC II** (HIV -^††^) | 217 | 8 | 5 | 61.5 | 152 | 52 | 74.5 | 6.0 | 13.3 | 96.8 | 2.4 | 0.5
Womack et al., 2000^ 62 ^ | HC II | 2140 | 174 | 41 | 80.9 | 1185 | 740 | 61.6 | 10.0 | 19.0 | 96.7 | 2.1 | 0.3
Wright et al., 2000^ 64 ^ | HC II | 1365 | 47 | 9 | 83.9 | 1081 | 228 | 82.6 | 4.1 | 17.1 | 99.2 | 4.8 | 0.2
Total all HC II | | 6793 | 410 | 76 | 84.4 | 4962 | 1345 | 78.7 | 7.2 | 23.4 | 98.5 | 4.0 | 0.2
HCII excluding HIV + | | 6544 | 371 | 72 | 83.7 | 4877 | 1224 | 79.9 | 6.8 | 23.3 | 98.5 | 4.2 | 0.2
HCII in populations with prevalence <10% | | 5425 | 249 | 56 | 81.6 | 4004 | 1116 | 78.2 | 5.6 | 18.2 | 98.6 | 3.8 | 0.3

*HPV, human papilloma virus.

^†^ Sens, sensitivity.

^‡^ Spec, specificity.

Prev, prevalence.

^ll^ PPV and NPV, positive and negative predictive value.

Pos LR and Neg LR, positive and negative likelihood ratio.

^#^ SHARP, SHARP detection system.

**HC, hybrid capture.

^††^ HIV, human immunodeficiency virus, where "+" indicates participants with HIV infection and "should be" indicates those without infection.

^‡‡^ Physician collected samples.

Five of the 6 HPV screening studies used Hybrid Capture II.^21,61-64^ To report aggregate estimates of performance for detection of HSIL, we calculated summary performance measures using the aggregate numbers of true positives, false negatives, true negatives, and false positives in these studies, with a combined total enrollment of 6,793 participants. In aggregate, the sensitivity of Hybrid Capture II for detecting HSIL was 84.4%; specificity was 78.7%; positive predictive value, 23.4%; and negative predictive value, 98.5%.

These Hybrid Capture II estimates include an easily delineated group of women with HIV infection who had high prevalence of HSIL - 17.3% among the HIV-infected women in the Womack and colleagues cohort.^ 63 ^ Excluding HIV-infected women from the aggregate test performance estimates should have the largest influence on the predictive values, because these are determined by prevalence. However, these women make up a small portion of the overall total and the estimates of performance characteristics are essentially unchanged. To further describe Hybrid Capture II performance in low-prevalence populations, we calculated aggregate data for only those studies^21,62,64^ or arms of studies^ 63 ^ in which the prevalence of HSIL was 10% or lower. In these conditions, sensitivity is somewhat lower at 81.6%; specificity is similar at 78.2%; positive predictive value is reduced to 18.2% and negative predictive value is 98.6%, essentially unchanged compared to the estimates that include all studies using Hybrid Capture II regardless of prevalence.

#### HPV Screening for Detection of Low-Grade Cervical Changes

Four of the screening studies include data that allow estimation of test performance if LSIL is included among the lesions targeted for detection by HPV testing. The sensitivity of a positive Hybrid Capture II test for high-risk HPV types for detecting histology-proven LSIL or greater ranged from 45.2% to 85.9%.^21,62,64^ Specificities were between 47.0% and 96.7%.^21,62,64^ Details of test performance for detecting low-grade and higher lesions are provided in Table 9.

Table 9. Performance of Screening HPV* Testing for Detection of Low-grade or More Severe Abnormalities

Article | Test Method | Total N | True Pos. | False Neg. | Sens^†^ | True Neg. | False Pos. | Spec^‡^ | Prev | PPV^\|\|^ | NPV^\|\|^ | Pos. LR | Neg. LR
Cuzick et al. 1999^ 21 ^ | SHARP^#^ | 2988 | 81 | 45 | 64.3 | 2767 | 95 | 96.7 | 4.22 | 46.0 | 98.4 | 19.4 | 0.43
| HC I** | 1285 | 29 | 18 | 61.7 | 1011 | 227 | 81.7 | 3.66 | 11.3 | 98.3 | 3.4 | 0.50
| HC II | 1703 | 36 | 23 | 61.0 | 1564 | 80 | 95.1 | 3.46 | 31.0 | 98.6 | 12.5 | 0.43
Womack et al. 2000^ 63 ^ | HC II (HIV+^††^) | 249 | 73 | 12 | 85.9 | 77 | 87 | 47.0 | 34.1 | 45.6 | 86.5 | 1.62 | 0.30
| HC II (HIV-^††^) | 217 | 14 | 17 | 45.2 | 140 | 46 | 75.3 | 14.3 | 23.3 | 89.2 | 1.83 | 0.73
Womack et al. 2000^ 62 ^ | HCII | 2140 | 359 | 202 | 64.0 | 1024 | 555 | 64.9 | 26.2 | 39.3 | 83.5 | 1.82 | 0.56
Wright et al. 2000^ 64 ^ | HC II | 1365 | 78 | 18 | 81.3 | 1072 | 197 | 84.5 | 7.6 | 28.4 | 98.3 | 5.42 | 0.22
Total all HC II | | 5674 | 560 | 272 | 67.3 | 3877 | 965 | 80.1 | 14.7 | 36.7 | 93.4 | 3.4 | 0.40
HC II excluding HIV+ | | 5425 | 487 | 260 | 65.2 | 3800 | 878 | 81.2 | 13.8 | 35.7 | 93.6 | 3.5 | 0.40
HC II in populations with prevalence <10% | | 3068 | 114 | 41 | 73.5 | 2636 | 277 | 90.5 | 5.1 | 29.2 | 98.5 | 7.7 | 0.30

*HPV, human papilloma virus.

Prev, prevalence.

^ll^ PPV and NPV, positive and negative predictive value.

^†^ Sens, sensitivity.

Pos LR and Neg LR, positive and negative likelihood ratio.

^‡‡^ Physician collected samples.

^‡^ Spec, specificity.

^#^ SHARP, SHARP detection system.

**HC, hybrid capture

^††^ HIV, human immunodeficiency virus, where "+" indicates participants with HIV infection and "should be" indicates those without infection.

Cuzick and colleagues study of women having screening at their primary care providers' offices in the United Kingdom is likely the most comparable to screening in the United States, the relative performance of the SHARP (Digene Corp.) microtiter format PCR test and the Hybrid Capture II is of interest. Both tests delivered similar performance: sensitivity of 64.3% versus 61.0%; specificity of 96.7% versus 95.1%; negative predictive value of 98.4% versus 98.6%, positive likelihood ratios of 19.4 versus 12.5, and negative likelihood ratios of 0.43 for both tests. In some studies, Hybrid Capture I delivers test performance comparable to SHARP PCR and Hybrid Capture II.^61,65^ However, in the Cuzick et al. analysis (which allows direct comparison in the same cohort), the newer HPV testing modalities appear to be superior.

All of the studies that consider HPV and LSIL detection evaluated Hybrid Capture II. We calculated summary performance measures using the aggregate numbers of true positives, false negatives, true negatives, and false positives in these studies with a combined total enrollment of 5,674. In aggregate, the sensitivity of Hybrid Capture II for detecting LSIL or more severe lesion, was 67.3%; specificity, 80.1%, positive predictive value, 36.7%; and negative predictive value, 93.4%. Eliminating the HIV-positive women from the estimates,^ 63 ^ the aggregate positive predictive value falls slightly to 35.7%; negative predictive value is essentially unchanged at 93.6%; sensitivity is 65.2%; and specificity is 81.2%. Lastly, eliminating all groups with a 10% or greater prevalence of LSIL or higher lesions, the resulting performance is sensitivity of 73.5%; specificity, 90.5%; positive predictive value, 29.2%; and negative predictive value, 98.5%.

### Triage Use of HPV Testing

A proposed role for HPV testing is to serve as a diagnostic tool to facilitate triage of women with an abnormal Pap tests. To estimate its test characteristics in this role included 7 articles relevant to triage uses of HPV (Evidence Table 3B, Appendix C) that met the following criteria for inclusion:

1. HPV specimen obtained or processed (or both) only for women with abnormal cytologic diagnoses on Pap testing;
2. Performance of HPV for predicting presence of CIN evaluated by colposcopy and/or histology as the reference standard;
3. HPV test and reference standard applied within an average of 3 months; and
4. A validation of negative HPV results, such that a complete 2x2 table relating the HPV test findings to the reference standard can be completed.

Table 10 summarizes the study populations and severity of disease identified in populations included in the studies relevant to HPV testing as a triage tool. Although the majority of these studies required an abnormal Pap test for enrollment, we required only that the HPV test and the colposcopy and/or histology, and not Pap testing, occur within an average of 3 months' time. Two of these studies were conducted in countries in which initial ASCUS and/or low grade cytologic findings are followed by repeat Pap testing. Colposcopy is only done if repeat cytology suggests risk of a high grade lesion.^66,67^ This approach lengthens the time between the index Pap and the use of HPV testing and colposcopy. It also increases the probability that women undergoing colposcopy will have a histologic lesion. As a result of such cytology-based triage, the studies from Iceland and the Netherlands reflect a comparatively high prevalence of high grade lesions.^66,67^ This finding has implications for this report because the prevalence of high grade lesions in these studies is higher than one would expect if HPV testing were used as initial triage at the time of a first abnormal Pap test, and prevalence does influence diagnostic test characteristics. These studies may not be as informative for US clinicians because within our screening approach, HPV is most attractive as a triage tool for guiding management of patients with low grade cytologic abnormalities who will at the time of colposcopy have a much lower prevalence of high grade lesions.

Table 10. HPV Testing Among Women with Abnormal Pap Test Results*

Article | Population/ Referral Pap | Prevalence of LSIL (%) | Prevalence of HSIL (%) | Prevalence of Carcinoma (%)
Adam et al., 1998^ 71 ^ | 454 indigent Texan women referred for colposcopy after ASCUS or LSIL | LSIL = 55.3 | HGSIL = 14.5 | 4 cases invasive cancer = 0.40
Bollen et al., 1997^ 66 ^ | 190 consecutive Dutch women with mild or moderate dysplasia | LSIL = 57.8 | HSIL = 29.5 | No cases
Herrington et al., 1995^ 69 ^ | 167 British women referred for colposcopy for low grade cytologic findings (< CIN 1) | "wart virus changes" = 37.7 CIN 1 = 15.0 | CIN 2 = 7.2 CIN 3 = 16.8 | No cases
Hillemanns et al., 1999^ 72 ^ | 247 German colposcopy patients | CIN 1 = 7.3 | CIN 2/3= 15.4 | 2 cases invasive cancer = 0.81
Manos et al. 1999^ 68 ^ | 973 US HMO patients with ASCUS | LSIL = 12.8 | HSIL = 6.7 | 1 case invasive cancer = 0.1
Sigurdsson et al., 1997^ 67 ^ | 358 Icelandic women referred for colposcopy | CIN 1 = 16.5 | CIN 2 = 15.9 CIN 3 = 36.6 | 7 cases invasive cancer = 2.0
Sun et al., 1995^ 73 ^ | 520 US or Canadian women referred for colposcopy | LSIL = 31.0 | HSIL = 18.8 | 7 cases invasive cancer = 1.3

*HPV, human papilloma virus; LSIL, low-grade squamous intraepithelial lesion; HSIL, high-grade squamous intraepithelial lesion; CIN, cervical intraepithelial neoplasia

The indications for the colposcopy, including indications established for the purposes of research, vary across studies; this in turn also influences the spectrum of abnormalities identified. The study cohort in Iceland had a prevalence of 54.5% of high-grade lesions compared to 15.4% among German women referred for colposcopy. Similarly, among studies that enrolled patients based on cytology findings as an entry criterion (rather than referral for colposcopy), the criteria vary from ASCUS only^ 68 ^ to CIN 1 or CIN 2.^ 66 ^ This means that aggregating test performance characteristics across studies is problematic. The test characteristics of high-risk HPV testing for detecting HSIL as a triage tool are summarized in Table 11.

Table 11. HPV Testing as a Triage Tool Among Women with an Abnormal Pap Test for Detection of HSIL*

Author (Year) | Test Method | Total N | True Pos. | False Neg | Sens | True Neg | False Pos. | Spec | Prev HGSIL | PPV | NPV | Pos LR | Neg LR
Adam et al., 1998^ 71 ^ | Consensus PCR | 454 | 43 | 23 | 65.2 | 233 | 155 | 60.1 | 14.5 | 21.7 | 91.0 | 1.6 | 0.6
Bollen et al., 1997^ 66 ^ | SHARP PCR | 190 | 53 | 3 | 94.6 | 54 | 80 | 40.3 | 29.5 | 39.8 | 94.7 | 1.6 | 0.1
Herrington et al., 1995^ 69 ^ | Consensus PCR | 167 | 35 | 5 | 87.5 | 79 | 48 | 62.2 | 24.0 | 42.2 | 94.0 | 2.3 | 0.2
Hillemanns et al., 1999^ 72 ^ | HC II | 247 | 35 | 3 | 92.1 | 150 | 59 | 71.8 | 15.4 | 37.2 | 98.0 | 3.3 | 0.1
Manos et al., 1999^ 68 ^ | HC II | 973 | 58 | 7 | 89.2 | 582 | 326 | 64.1 | 6.7 | 15.1 | 98.8 | 2.5 | 0.2
Sigurdsson et al., 1997^ 67 ^ | Consensus PCR | 358 | 156 | 39 | 80.0 | 118 | 45 | 72.4 | 54.5 | 77.6 | 75.2 | 2.9 | 0.3
| HC I | 358 | 136 | 59 | 69.7 | 96 | 67 | 58.9 | 54.5 | 67.0 | 61.9 | 1.7 | 0.5
Sun et al., 1995^ 73 ^ | Consensus PCR | 520 | 87 | 18 | 82.9 | 145 | 270 | 34.9 | 20.2 | 24.4 | 89.0 | 1.3 | 0.5
| HC II | 520 | 83 | 22 | 79.0 | 181 | 234 | 43.6 | 20.2 | 26.2 | 89.2 | 1.4 | 0.5
Total all PCR | | 1689 | 374 | 88 | 81.0 | 629 | 598 | 51.3 | 27.4 | 38.5 | 87.7 | 1.7 | 0.4
Total all HC II | | 1740 | 176 | 32 | 84.6 | 913 | 619 | 59.6 | 12.0 | 22.1 | 96.6 | 2.1 | 0.3

*HPV, human papilloma virus; HSIL, high-grade squamous intraepithelial lesion.

Three strong studies selected the degree of Pap test abnormality a priori and then obtained histologic verification of HPV test performance. The group with the lowest risk of high-grade lesion at the time of evaluation was that assembled by Manos and colleagues within the Kaiser Permanente Medical Care Program in Northern California.^ 68 ^ They enumerated all women at 4 medical centers who had a Pap test during a 9-month period and invited all women with ASCUS to participate if they were not pregnant and did not have a history of treatment for cervical neoplasia in the prior six months. Sixty-one percent of patients with ASCUS enrolled in the study; participants were demographically similar to non-participants. In this setting the sensitivity of Hybrid Capture II testing for high-risk HPV to detect HSIL was 89.2%; specificity was 64.1%; positive predictive value, 15.1%; negative predictive value 98.8%. For detection of LSIL and more severe lesions, the sensitivity was 76.3%; specificity, 69.5%; positive predictive value, 37.8%; and negative predictive value, 92.4%.

Herrington and colleagues studied 167 patients with 99 with persistent "borderline" smear, 39 with "wart virus changes", and 29 with "mild dyskaryosis."^ 69 ^ Like women in the United States, German women with moderate or severe dysplasia are referred immediately for colposcopy and possible treatment. The group evaluated in this study is, therefore, much like the group for whom HPV triage would be of interest in the United States. In this setting, consensus PCR had sensitivity of 87.5%, specificity of 62.2%, positive predictive value of 42.2% and negative predictive value of 94.0% for detection of histology proven high-grade lesions.

Bollen and colleagues studied British women including only those with mild or moderate dysplasia or cytology.^ 66 ^ Of the test systems they evaluated in their patient population, SHARP PCR (for high-risk HPV types) was relevant to this review. The sensitivity for detecting HSIL was 94.6%; specificity, 40.3%; positive predictive value, 39.8%; negative predictive value, 94.7%. In these 3 cytology-defined studies as well as the colposcopy-referral studies, the negative predictive value of testing for high-risk HPV types is greater than 90%, suggesting the feasibility of using negative HPV results to lengthen the time until repeat Pap test and to reduce the number of women who have colposcopy.

#### Benefits

The benefits of HPV testing as a screening test, an adjunct to screening, or a triage tool are not documented in prospective cohort studies or trials evaluating outcomes among women who received conventional cytology only compared to an alternate strategy that includes HPV testing.

#### Risks

We did not identify any studies that explicitly addressed negative individual, health system, or societal consequences of HPV testing other than cost, which is addressed briefly below. Comments in various publications suggest potential risks fall within 6 categories of concerns listed below, but no literature addresses the likelihood of any of these reactions or their magnitude:

1. Focusing on HPV testing will strongly identify cervical dysplasia and cancer with sexually transmitted disease (STD) and will stigmatize those with the condition.
2. Identifying cervical dysplasia with a sexually transmitted virus will result in women who perceive themselves as at low risk for STD receiving less cervical cancer screening.
3. Diagnosis of HPV infection will provoke partner discord.
4. Diagnosis of HPV infection, given low-positive predictive value, will unnecessarily label some women as high risk.
5. Labeling women as infected with a high-risk HPV types will provoke anxiety that may have unpredictable consequences such as over-intervention or poor compliance with followup.
6. HPV testing could undermine the importance of cytologic screening with providers or patients.

#### Costs

Current costs and charges for HPV testing in clinical care vary widely by geographic location, test modality, laboratory contracts with vendors, and volume of specimens analyzed at the laboratory facility. At the University of North Carolina Healthcare System, the Hybrid Capture II test kit cost $43 in February 2001. The clinical laboratory fees were $125 for Hybrid Capture II testing and $160 for consensus PCR at the same time. As any other diagnostic modality, increased demand should eventually increase capacity, in part through competition, and lower costs. These market forces are not yet at work, and costs have not converged or declined.

For cost modeling purposes this uncertainty about the expense of the test can easily be handled by varying the model estimates of test cost. Adequate estimates of the cost of primary care office-based cervical cancer screening and resulting evaluation and treatment relevant to the US health care system are available.^ 32 ^ However, the remaining parameters required for cost-effectiveness analysis hinder such estimates. Factors such as repeatability of HPV test results, incidence and types of HPV by age category, rates of progression and regression of HPV, and sensitivity and specificity for predicting outcomes over varied intervals of time are inadequately defined for using HPV tests in screening.

No recent literature specific to the United States is available to model and compare effectiveness or costs of screening or triage uses of HPV testing that have been proposed. The most complete contemporary model to date, constructed based on the United Kingdom screening system, considered adding HPV to Pap testing, replacing Pap testing with HPV testing, and adding HPV testing to surveillance of low-grade lesions versus continuing conventional surveillance. The authors concluded: "The uncertainty, as expressed by the differences between models, is so large, the results are inconclusive. Adding HPV testing to cervical cancer screening may or may not improve the (cost) effectiveness of screening. There are relatively few longitudinal HPV screening studies with enough time lapse between measurement points to decrease uncertainty."(p. 115)^ 70 ^ When such models are generated they are further challenged by the lack of existing outcomes data even on a small scale to support or falsify the overall model or its components.

Overall, the quality of this literature is adequate for assessing the performance characteristics of the newer HPV testing methods. Hybrid Capture II and consensus PCR have good sensitivity and negative predictive value. This suggests a strong potential for a role in determining screening intervals and in triaging patients with abnormal cytology, especially among older women who have more stable HPV profiles. However, the quality of the literature is limited for the purposes of making decisions about implementing HPV testing in the US population for general screening or triage use. No published randomized trials or prospective comparisons in suitable populations were identified. In the absence of studies that relate the screening tools used to outcomes, the linkages between comparative test performance of HPV and cytologic screening tools are insufficient to judge the implications of preferentially using one combination of screening tools over another.