# Methods

This chapter documents procedures that the RTI-UNC Evidence-based Practice Center (EPC) used to develop this systematic evidence review (SER) on cervical cancer screening. We document the general search strategy and criteria, specify the final search terms, describe procedures for further review of abstracts and publications, explain methods used to extract information from included articles, introduce approach to summarizing findings, and detail the peer review process.

During preparation of the evidence report, EPC staff collaborated with two current members of the US Preventive Services Task Force (USPSTF). Our collaboration took place by conference call, electronic mail, traditional mail, and fax. We presented steps of the development of this SER at USPSTF meetings in February, May, and September 2000. A key consideration for the September 2000 meeting was the timing of the report with respect to the anticipated publication in the near future of results from the first randomized trial comparing cervical cancer screening tools.

## Literature Search Strategy

Our key questions guided the preliminary review of the literature. We have emphasized the identification of new research, existing syntheses of the literature, and opinions of leading medical and policy organizations, especially those reported since the completion of the second Guide to Clinical Preventive Services. ^ 4 ^ As part of the preliminary search, we took four steps: (1) reviewed prior USPSTF findings; (2) obtained current recommendations and/or guidelines for cervical cancer screening from the American Academy of Family Physicians, American Cancer Society, American College of Obstetricians and Gynecologists, Australian Health Ministers' Advisory Council, Canadian National Workshop on Screening for Cancer of the Cervix, the National Strategic Plan for Early Detection and Control of Breast and Cervical Cancer, and the UK National Health Service Cervical Cancer Screening Program; (3) identified recent relevant systematic reviews in the medical literature; and (4) consulted with USPSTF liaisons for this topic.

### Inclusion/Exclusion Criteria

We established overall inclusion and exclusion criteria a priori. Tables 3 and 4 present results of the search strategy with specific search terms.

Our search strategy, developed with the assistance of the RTI-UNC EPC research librarian who specializes in evidence-based literature review is described in Table 4. Using a selection of sentinel publications relevant to each key topic that were captured in the original broad search (Table 3), we specified searches that would provide focused identification of articles related to each key question. However, further specifying exhaustive searches for each question resulted in oversight of articles likely to be relevant as judged by missing sentinel articles. Key Question 1 about older age, older age and interval, and hysterectomy was the most difficult search to focus. As a result, we took an exhaustive approach to categorizing all articles obtained in the larger search. This process is described in detail below.

Table 3. Overall Inclusion and Exclusion Criteria

Element | Inclusion | Exclusion
Databases | MEDLINE | Other databases
Languages | English | Other languages
Populations | Human | Animal studies
Study Design | Primary research reports, cost-effectiveness analyses, meta-analyses, systematic reviews | Letters, editorials (i.e., no original data)

Table 4. Literature Search Results (1995-2000)

Step | Search History | Results
1 | Explode cervical neoplasm | 29,318
2 | Explode cervical dysplasia | 2,331
3 | Explode mass screening | 44,349
4 | Explode vaginal smears and screening | 2,302
5 | 1 or 2 | 29,913
6 | 3 or 4 | 45,324
7 | 5 and 6 | 3,256
8 | Limit 7 to human and English language and year = 1995-2000 | 962

### Literature Reviewed

#### Citation Database

We used the search strategy in Table 4 to identify potentially relevant publications. From our first search (December 1999) we imported references into a ProCite database, which enumerates, stores, manages, and retrieves bibliographic citations; we also recorded the fate of all identified publications as they were screened for inclusion. We repeated the search in June 2000, eliminating duplicate references and adding the new additions to the ProCite database.

### Screening of Articles

Two EPC staff independently reviewed the titles and abstracts of the articles identified and excluded those that did not meet eligibility criteria. If the reviewers disagreed, we carried the article in question forward to the next stage in which we then reviewed the full article and made a final decision about inclusion or exclusion. At each step we recorded the fate of the article in the ProCite database. Table 5 presents the disposition of articles identified as potentially relevant publications (for review of the full article), summarizing the number of publications at each step and their categorization.

Table 5. Disposition of Articles Identified by Literature Search

Categorization by Abstract Review | Total Identified | Number Excluded | Retained for Background | Retained for Review
Key Question 1: Who should be screened? | 351 | 205 | 28 | 118
Key Question 2: New cytology methods for screening | 196 | 143 | 5 | 48
Key Question 3: What is the role of HPV testing? | 64 | 31 | 3 | 30
Commentary/opinion, guidelines, methodologic critique, reviews | 128 | 96 | 32 | ----
Methods to promote uptake and continuance of screening or improve follow-up of abnormal results | 223 | 216 | 7 | ----
Total | 962 | 691 | 75 | 196

Limiting the exhaustive search (search 8, Table 4) to identify only articles that reported on trials, we identified 57 articles. Of these, 25 are primary reports of randomized trials: 15 address methods to promote uptake and continuance of appropriate screening; 3 examine methods to improve follow-up of abnormal screening findings; 3 compare tools for collecting cytologic samples (i.e., type of spatula, brush or swab); 3 investigate patient education and satisfaction; and 1 compares cytology alone to cytology with cervicography as a primary screening modality. This exercise confirmed our assessment that few data would be available from randomized controlled clinical trials to inform our review.

Because final inclusion criteria were closely linked to the intent of the key question, we give greater detail about selection of articles for each of the key questions below. Table 5 summarizes the disposition of the articles identified in the literature search and the number of full articles on each topic retained for review.

#### Key Question 1: Screening Among Older Women and After Hysterectomy

The majority of the relevant literature identified for Key Question 1 is based on site-of-care or population-based prospective and retrospective studies and case-control studies. The large number of full articles that we retained for final abstraction reflected the need to examine the articles themselves to determine whether they provided data on benefits and risks of screening for particular groups (i.e., women age 65 and older) and in sufficient detail to clarify the relative performance of different screening intervals. We specifically sought articles that evaluated clinical risk prediction tools for assigning screening interval. Samples of the screening forms used to document decision making about inclusion of articles for Key Questions 1A and 1B appear in Appendix B.

In total, we screened 118 full articles to determine relevance. Of these, we retained 42 articles for Key Question 1A and 1B: 14 for full abstraction and 28 for supplementary information.

#### Key Question 2: New Technologies for Cytology

Although our search strategy identified articles since 1995 relevant to Key Question 2 on new methods for preparing or evaluating cytology, we conducted full abstraction of only those publications that had appeared since completion of the AHCPR Evidence Report/Technology Assessment, Number 5: Evaluation of Cervical Cytology prepared by a team at the Duke Medical Center EPC.^ 32 ^ Working with colleagues at the Duke EPC, we applied criteria and data extraction techniques that result in comparable reporting formats between the two evidence reviews. This approach allows us to streamline preparation of this report while capitalizing on the data previously collected to describe the performance characteristics of new cytology technologies.

The Evaluation of Cervical Cytology evidence report had several goals, including developing a model to estimate the costs associated with cervical cancer screening, evaluation, treatment, and follow-up of cervical cytologic abnormalities and the costs of treatment and follow-up of cervical cancer. To accomplish their modeling goals and make the best use of the existing literature, the Duke EPC included studies in which relative performance of new technologies could be assessed (e.g., use of computerized rescreening compared to conventional cytology alone) through use of expert adjudication of cytology findings with clinical confirmation of at least 50% of high-grade lesions.

Our team elected in advance of the literature review to focus primarily on studies that used clinical confirmation of cytology by colposcopy, cervical biopsy, or both (see Key Question 2 Screener in Appendix B). Specifically, we required that the new method being evaluated be

- Obtained as a screening test or adjunct to screening (i.e., not as follow-up of documented disease);
- Compared with a reference standard of histology or colposcopy;
- Verified by use of the reference standard within an average of three months interval from the screening sample; and
- Reported in a fashion that allows completion of a 2x2 table relating the new method to the reference standard.

In the case of new Pap testing technologies, these strict criteria also required that performance of the new test could be compared to that of conventional Pap testing.

We screened 48 full articles to determine relevance for updating Key Question 2. Overall, based on these strict inclusion criteria, only three articles were eligible for inclusion. Virtually all excluded articles failed to use a clinical reference standard or did so only among those with a positive test without confirmation of either all or a subset of test negative tests. Because a secondary goal of our work was to update the Cervical Cytology report, we relaxed our criteria to include studies that would have met the criteria for that report (which allows for a cytology reference standard). In total, we abstracted three high-quality articles and five other articles for the evidence tables and retained five for supplementary information.

For completeness, we added these new studies to the new technologies evidence table originally produced for the Evaluation of Cervical Cytology. The updated table is reproduced in its entirety in this report as Evidence Table 2, Appendix D. We did not identify any studies that report rates of outcomes over time, such as rates of cervical dysplasia or cervical cancer among cohorts of women receiving screening using conventional cytology compared to either new technologies alone, or to a system that adds a new technology to conventional cytology. We found no publications of randomized trials comparing individual outcomes by screening modality.

#### Key Question 3: What is the Role of HPV Testing?

After consultation within our team and with the USPSTF in a February 2000 conference call, we restricted this portion of the review to recent literature. Although the previous Guide to Clinical Preventive Services recommended against use of HPV testing as an ancillary test within a screening strategy, we believed that the laboratory technology for HPV identification, classification, and measurement of viral DNA incorporation has changed so rapidly that a review of the recent literature was appropriate.

Our search identified 64 abstracts potentially relevant to this topic; once again the individual review of all abstracts identified more articles for full review than restriction of search #8 in Table 4 using a variety of electronic search strategies. In total, we screened 30 full articles to determine relevance. The strict inclusion criteria for assessing screening studies were applied to the HPV literature. Studies on this topic were more likely to include histologic verification of test results, although no prospective comparisons of individual patient outcomes or published randomized trials examine the efficacy or effectiveness of HPV testing in clinical use. Overall, 16 of these 30 articles were included for this question, 13 for full abstraction and 3 for supplementary information.

#### Cost and Harms

The screening worksheet for each key question included additional questions to identify articles that reported on cost, cost-effectiveness, and harms, including psychological distress. When we flagged an article as potentially providing background on cost, cost-effectiveness, or other relevant economic evaluations, we subjected the article to further review by another team member.

We reviewed 21 articles, the vast majority of which were articles that examined the cost of operating national screening systems within single payer health systems across Europe. As our goal was not cost evaluation or modeling, or critique of that literature, we wished to retain only the most relevant publications for this SER. To be considered, we required that the article reflect the cost or charges of using the screening modality in a primary care setting in the United States and that it compare new methods with conventional methods. We included four publications relevant to cost, including an evidence report from the Agency for Healthcare Research and Quality (AHRQ), as background references.

In consultation with our team members, USPSTF liaisons, and USPSTF members in telephone conference, we elected not to examine relative rates of assignment of the diagnosis of atypical squamous cells of uncertain significance (ASCUS) and cervical intraepithelial neoplasia I (CIN1) as a potential indicator of "harm." Many such low-grade lesions regress and watchful waiting may be as effective as intervention; however, evidence at this time is insufficient to assert that detection of low-grade changes confers no benefit and only poses potential harm. Nonetheless, we have emphasized that optimal screening systems maximize identification of high-grade changes. Similarly, we have noted the potential harm of undergoing unnecessary evaluation and/or procedures, whether for diagnosis (such as colposcopy) or treatment (such as loop electrosurgical excision procedure or LEEP), but we have not further examined the harms of these procedures themselves.

## Literature Synthesis and Preparation of Systematic Evidence Review

### Data Abstraction and Development of Evidence Tables

We abstracted information about study objective, design, population, conduct, outcomes, and quality into designated sections and positions within evidence tables created in Microsoft Excel and Word. Two readers, a methodologist and a clinician-researcher, reviewed each article in an evidence table. The order of review by each pair of readers was not mandated, and both parties checked calculations of summary data, such as test sensitivity, that was generated for the tables.

To assess systematically comparable features of included articles and assure consistency, we used a checklist of potential indicators of study quality for the literature related to each key question. For Key Questions 2 and 3, we provide scores using the system designed for the Evaluation of Cervical Cytology evidence report, which fully documents development of the scoring system.^ 32 ^ For Key Question 1, we incorporated indicators more relevant to cohort research, eliminating those items related purely to evaluation of diagnostic tests. Scores were assigned separately by two individuals and discussed as a group in the rare cases of substantial differences of opinion. These scores and a global categorization of the internal and external validity of the reviewed research contributed to grading of individual articles and the body of relevant literature consistent with USPSTF methods.^ 33 ^

### Peer Review Process

Upon completion of the draft SER incorporating the review at the September 2000 USPSTF meeting, we conducted a broad-based external review of the draft. Among the outside reviewers are representatives of key primary care professional organizations that have formal ties to the USPSTF, a representative of the Canadian Task Force on Preventive Health Care, representatives of other professional societies, clinical experts in the area of cervical cancer screening, members of the AHRQ staff, and representatives of other federal agencies. Appendix A lists the names and affiliations of all peer reviewers. We took into account the comments of these reviewers in developing the final version of this SER.