# Introduction

## Background

Since introduction of cytologic screening for cervical cancer using the Papanicolaou (Pap) test in the 1950s, the incidence of invasive cervical cancer in the United States has fallen more than 100%.^ 1 ^ No other cancer screening program has been more successful. This fall occurred despite an increase in risk factors for cervical cancer, such as younger age at initiation of sexual intercourse, more sexual partners in a lifetime, and greater prevalence of human papilloma virus (HPV) infection and cigarette smoking.

Success in prevention reflects three factors: (1) progression from early cellular abnormalities, termed low-grade dysplasia, through more severe dysplasia, to carcinoma in situ and invasive cancer is generally slow, allowing time for detection; (2) associated cellular abnormalities can be identified; and (3) effective treatment is available for premalignant lesions. Consequently, invasive squamous cell carcinoma of the uterine cervix is a highly preventable disease.

Introduction of screening programs in populations naïve to screening reduces cervical cancer rates by 60% to 90% within three years of implementation.^2,3^ This reduction of mortality and morbidity with introduction of screening with the Pap test is consistent and dramatic across populations. As a result, Pap testing is one of the few preventive interventions that has received an "A" recommendation from the US Preventive Services Task Force (USPSTF) in the absence of randomized trials demonstrating effectiveness.^ 4 ^

### Uniform Terminology for Cervical Lesions

Figure 1 depicts the relationship between varied systems of nomenclature for describing cytologic and histologic findings. In this report we use terminology from the Bethesda System -- low-grade squamous intraepithelial lesion (LSIL) and high-grade squamous intraepithelial lesion (HSIL) to describe cytology findings. When possible, we use the cervical intraepithelial neoplasia (CIN) -- specifically, categories CIN 1-3 -- to refer to histologic findings. As necessary, we present histology findings for the groupings LSIL or HSIL if this is the most detailed summary of results provided by the investigators.

Figure 1. Map of Cervical Cytology Classification Schemes

Classification System | Within Normal Limits | Benign Cellular Changes | Epithelial Cell Abnormalities
The Bethesda System^ 28 ^ | Normal | Infection Reactive Repair | ASCUS^*^ | Squamous Intraepithelial Lesion (SIL) | | | | | Invasive Carcinoma
The Bethesda System^ 28 ^ | Normal | Infection Reactive Repair | ASCUS^*^ | Low Grade (LSIL) | | High Grade (HSIL) | | | Invasive Carcinoma
Richart^ 29 ^ | Normal | - - - - | | Condyloma | Cervical Intraepithelial Neoplasia (CIN) | | | | Invasive Carcinoma
Richart^ 29 ^ | Normal | - - - - | | Condyloma | Grade 1 | Grade 2 | Grade 3 | | Invasive Carcinoma
Reagan^ 30 ^ | Normal | Atypia | | Mild Dysplasia | Moderate Dysplasia | Severe Dysplasia | In situ Carcinoma | | Invasive Carcinoma
Nyirjesy^ 31 ^ | I | II | | III | | | IV | | V

Source: McCrory et al., 1999^ 32 ^

* ASCUS, Atypical squamous cells of uncertain significance.

### Burden of Suffering

In the United States, approximately 12,800 new cases of cervical cancer are diagnosed and 4,800 deaths occur each year.^ 5 ^ Incidence of cervical cancer is decreasing; US rates have decreased from 14.2 new cases per 100,000 women in 1973 to 7.8 per 100,000 in 1994. For each woman with invasive disease, there will be 4 with carcinoma in situ and 10 with cervical dysplasia.^ 6 ^ Despite falling incidence, cervical cancer remains the ninth most common cause of cancer deaths.^ 5 ^ Of the cancer prevention goals established in Healthy People 2000, including colorectal, lung, and breast cancer, cervical cancer mortality rates were the furthest off target at the mid-course review. The target for cervical cancer was reduction of mortality to 1.3 deaths per 100,000 women; the current rate remains near 2.7 deaths per 100,000, down only slightly from 2.8 per 100,000 in 1987.^ 7 ^

Detection of cervical cancer in its earliest stages is lifesaving, as survival of cancer of the cervix uteri depends heavily on stage at diagnosis. Although 91.5% of women will survive 5 years when the cancer is localized, only 12.6% will survive distant disease.^ 1 ^

### Epidemiology

#### Risk Factors

Squamous cell carcinoma of the cervix and its cytologic precursors are conditions of sexually active women. Infection with high-risk strains of HPV, generally acquired sexually, is the most important risk factor for cervical cancer. The role of HPV is described in greater detail below.

Risk factors relating to sexual behavior that are associated with increased risk include onset of intercourse at an early age and a greater number of lifetime sexual partners. These behavioral risks appear to persist even after controlling for effects of HPV infection.^ 8 ^ A higher number of lifetime sexual partners in the male partners of cervical cancer cases compared to controls has also been noted in case-control studies.^ 8 ^ Occupations are related to cervical cancer only through relationships with sexual behavior.^ 8 ^ Cigarette smoking is the only nonsexual behavior consistently and strongly correlated with cervical dysplasia and cancer, independently increasing risk two- to fourfold.^9-11^ In the United States, black race and low socioeconomic status are associated with increased risk. Recently, attention has been drawn to a positive family history as a plausible risk factor.^ 12 ^

#### Role of Human Papilloma Virus

HPV plays a central role in the development of cervical cancer. Using modern HPV detection methods, 95% to 100% of squamous cell cervical cancer and 75% to 95% of high-grade CIN lesions have detectable HPV DNA.^13-15^

HPV is a double-stranded DNA virus. The virus is transmitted to the cervix and vaginal tissues primarily by sexual intercourse.^16,17^ HPV can infect and persist in vulvar, vaginal, and cervical tissue throughout a lifetime. This family of viruses includes those responsible for genital condylomata or warts, squamous cell carcinomas of the genital tract including vaginal and vulvar cancers, and cervical cancer. More than 70 strains or types of HPV have been classified. For instance, HPV Types 6 and 11 cause warts; other types have oncogenic properties.

The best characterized types associated with cervical cancer are Types 16 and 18.^ 18 ^ These are officially recognized by the International Agency for Research on Cancer (IARC) and the World Health Organization (WHO) as carcinogenic infectious agents. The primary difference between "oncogenic" and "non-oncogenic" virus is the interaction of two viral genes, E6 and E7, that influence cell cycle control mechanisms. Oncogenic E6 and E7 gene products can "cripple" a normal cell's ability to control cell proliferation, which in some instances leads to cancer.

HPV is a necessary but not sufficient precursor of squamous cell carcinoma of the cervix. Among women without cervical cytology abnormalities at baseline, those with high-risk HPV types have a relative risk of developing high-grade cervical lesions (CIN 2 - 3, CIS) that is 58- to 71-fold higher than the risk for those without detectable HPV.^19,20^

The natural history of HPV acquisition, clearance, persistence, and possible re-infection is complex. To promote cervical cancer abnormalities, the virus must become integrated into the host genomic DNA. This event, which is essential for cancer progression, appears to be rare. In the absence of viral integration, the normal viral lifecycle produces morphologic changes in the cervical epithelium characteristic of low-grade dysplasia (LSIL). With viral integration, the oncogenic effect of the E6 and E7 proteins is enhanced and cellular changes characteristic of high-grade dysplasia and ultimately cancer are observed.^21,22^

Inter-related host factors such as age, nutritional status, immune function, smoking, and possibly silent genetic polymorphisms modulate incorporation of viral DNA. Studies of the time required from infection to incorporation are challenging to interpret because assays for viral DNA integration are difficult to perform.^ 18 ^ Taken as a whole, however, nearly 100% of cases of carcinoma in situ and cancer are estimated to have integrated HPV DNA compared to a small minority of low-grade lesions.^ 15 ^

The transition time from simple viral infection to integration of DNA is unknown and may be influenced by the risk profile of population studied. For instance, although the prevalence of HPV infection is higher among immunocompromised hosts such as HIV-infected women, the speed of progression to cervical cancer is not increased. Natural history studies confirm that in the vast majority of cases, the course of infection and cervical abnormalities that progress do so in an orderly fashion from less severe to more severe lesions; de novo HSIL with HPV incorporation appearing in a short interval is rare. Thus, the sequence associated with HPV infection and development of cervical cancer is as amenable to surveillance as are cytologic changes.

In the United States, peak incidence and prevalence of HPV infection occur among women under age 25.^ 23 ^ More than 30% of postmenopausal women, however, have detectable HPV DNA using polymerase chain reaction (PCR) detection methods.

#### Screening Failures

In the United States, incident cases of squamous cell carcinoma can be attributed to different categories of failures of screening. Between 50% and 70% of cancer cases occur among women who have never been screened or who have not been screened within the past 5 years.^24,25^ Among women who have been screened, failures may occur in 3 ways. First, abnormalities may be identified by screening but not properly treated as a result of patient or provider failure to follow-up the abnormalities; this may occur in approximately 22% to 63% of those who receive proper screening. Second, serious abnormalities may not be present at the time of screening, and progression occurs between recommended screening intervals. When the interval is annual, such progression is rare; with 3-year intervals, this may happen in up to 50% of diagnosed cases.^ 26 ^ Progression is more common among women under 45 years of age. Third, abnormalities may be present but are not detected by the screening test (approximately 14% to 33%).^24,25^ The last category of failures, those related to the screening test, can be further subdivided into those that represent sampling error (cells from the abnormal area were not obtained and so could not be identified in the specimen) and those that reflect detection error (the abnormal cells are included in the specimen and are not identified as abnormal).

### Screening Tools

This report is focused on cervical cancer screening tools for clinical use in primary care settings. We consider traditional cytology and new cytologic technologies that are currently available to practitioners. HPV testing to identify specific types of HPV is less broadly available. Some HPV test methodologies such as Southern blot are appropriate as a gold-standard assay but not practical for widespread implementation in a cervical cancer screening program. As a result, we have focused on HPV tests suitable for high-volume use as part of primary clinical care. Basic descriptions of available cytologic and HPV screening tools are provided below.

#### Cervical Cytology: Conventional and New Technologies

Ordinarily, cervical cancer screening specimens are obtained at the time of pelvic examination during the portion of the examination when a speculum is used to visualize the cervix and obtain a sample for cytology. The goal of sampling for cytology purpose is to sample the transformation zone: that area of the cervix where physiologic transformation from the columnar cells lining the endocervical canal to the squamous cells covering the ectocervix occurs. Cervical dysplasia and cancers arise in the transformation zone. The transformation zone is easily sampled in younger women because it is on the surface of the cervix. With increasing age, however, the transformation zone is more likely to be higher in the endocervical canal.

Various sample collection tools are available to accomplish the goal of sampling both the ectocervix and the endocervix. Meta-analysis of randomized trials supports recommendations for combined use of a spatula, preferably an extended tip spatula, for sampling the ectocervix and a brush for sampling the endocervix.^ 27 ^

Conventional cervical cytology specimens are prepared by using the collection tool to smear the specimen onto a glass microscope slide while the woman is in the examination room. Two slides or two distinct areas of the same slide are prepared to represent the ectocervical and endocervical samples. The slides are then immediately sprayed with or placed in fixative. Slides are sent to the cytology laboratory and read by technicians who review the entire slide at 10x magnification, systematically in 2mm sections.

Thin layer cytology is a variation of conventional cytology. The Food and Drug Administration (FDA) has approved two systems: they are ThinPrep^®^ (Cytyc, Boxborough, MA) and AutoCyte PREP^®^ (TriPath Imaging, formerly Autocyte, Burlington, NC), approved in May 1996 and June 1999, respectively. Specimens are collected in the same fashion as those for conventional cytology; however, rather than smearing the sample onto slide(s), the sample is suspended in the fixative by stirring the specimen collection spatula and brush in the fixative solution. The container is sealed and the specimen sent to the cytology laboratory in solution rather than on slides; this theoretically improves the probability of transferring a representative sample of cells to the slide. In the laboratory, technicians disperse the sample in the fixative and then collect the cells on a filter and transfer them to a microscope slide in a monolayer. Immediate fixation and uniform spread of the cells are designed to reduce detection errors by assuring that cells are well preserved, not obscured, and more easily assessed by cytology technicians.

Both conventionally prepared and thin layer specimens read by cytotechnologists are subject to random manual rescreening of slides that were interpreted as normal at a minimum rescreening rate of 10%, as required by the Clinical Laboratories Improvement Amendments (CLIA) of 1988 (Final Rule, Federal Register, 1992).

Computerized rescreening is designed to automate rescreening of Pap smears initially read as negative by a cytotechnologist. PapNet^®^ (TriPath Imaging, Inc.) uses neural-network technology to interpret computerized images of the Pap slide. The system, approved by the FDA for rescreening use in December 1995, identifies cells or other material on negative Pap slides that require review and creates a summary display of up to 128 images that may contain abnormalities. A cytotechnologist then reviews the summary images and can also return to the original slide using light microscopy. Several countries allow use of PapNet as a primary screening as well as a rescreening technology, and the literature contains studies of both forms of use.

Algorithm-based rescreening identifies slides that exceed a selected probability for containing abnormal cells. The AutoPap^®^ 300QC system (Neopath, Inc. -- when reviewed, now TriPath), FDA approved in May 1998, can be set for different thresholds that result in 10%, 15%, or 20% review rates. Because a classification algorithm is applied, the slides selected for review are more likely to contain abnormalities than are negative Pap slides randomly selected for review. The system is reported to identify 70% to 80% of those slides misdiagnosed as normal (i.e., false negatives) at the time of manual screening. AutoPap is also employed for both routine screening and rescreening purposes outside the United States, and publications evaluate both types of use.

We excluded review of the performance of AutoSCREEN, a product for interactive, computer-assisted screening and rescreening. Its manufacturers no longer produce it after a corporate merger between the AutoPap parent company and the original producer. We also have not reviewed approaches that require additional time, equipment, expertise, or materials at the time of the clinical pelvic examination, such as speculoscopy, screening colposcopy, or cervicography to photograph the cervix. These are not suitable for widespread implementation in the United States.

#### Tools for HPV Testing

Cellular changes associated with HPV infection can be seen on visual examination of cervical cytologic or biopsy specimens and, to a lesser degree, at colposcopy. However, the presence of these changes is neither sensitive nor specific.

Direct HPV testing methods for assessing the presence and type of HPV are more promising; they rely on identification of HPV viral DNA. Some versions of testing are qualitative, detecting only the presence or absence of HPV DNA; some are quantitative, estimating the viral burden; and some methods allow assessment of degree of integration of HPV into the host genome. Tests differ in the method for processing the DNA analyzed, the quantity of specimen required, and difficulty of analysis.

Because the family of HPV viruses is large, and because only a small group of those types is associated with cervical dysplasia and cervical cancer, tests that identify specific viral types or panels of high-risk viral types are preferable to detection of all HPV types. A multitude of laboratory methods has been applied to studying HPV. However, these approaches are not all equally applicable to screening. Considering the reliability and relative performance characteristics of the assays in controlled settings in the laboratory and their potential for application to screening, we have adopted the classification of HPV testing technologies presented in Table 1.

Table 1. Technical Characteristics of HPV Testing Methods

Test Technique | Low Sensitivity and Specificity | High Sensitivity and Specificity | Complex Execution/Low Potential for Automation | Suitable for High Throughput/ Amenable to Automation
Southern blot | [image] | | [image]
In situ hybridisation protocols* | [image] | | [image]
Dot blot procedures | [image]
Hybrid Capture I | [image] | | [image]
Hybrid Capture II | | [image] | | [image]
PCR | | [image]
Consensus PCR^†^ | | [image] | | [image]

Source: Adapted from Cuzick et al., 1999.^ 21 ^

* Includes Flourescent In Situ Hybridisation (FISH).

†PCR, polymerase chain reaction.

This is a modification of the classification used by John Cuzick, his co-authors, and an expert panel of the Health Technology Assessment Board of the UK National Health Service in their Systematic Review of the Role of Human Papillomavirus Testing Within a Cervical Cancer Screening Program. ^ 21 ^ Based on consultation within our team, with our USPSTF liaisons, and with other experts, we have focused our review on evaluation of clinically collected cervical samples using Hybrid Capture II (HCII) and on type-specific, the SHARP detection system, or conventional consensus PCR.

## Health Care Interventions

Reduction of morbidity and mortality associated with squamous cell carcinoma of the cervix is the ultimate goal of screening. The screening system used must be acceptable to patients and providers and detect abnormalities that are amenable to intervention. The broad spectrum of cervical abnormalities detected by cytology, from low-grade changes to carcinoma in situ, is a particular challenge. HSIL warrants immediate evaluation by colposcopy, biopsy, and endocervical curettage. Patients with CIN 3/CIS receive definitive intervention, such as conization by loop electrosurgical excision procedure (LEEP), laser, or cold knife, to remove the transformation zone and confirm that no invasive disease is present. Patients with CIN 2 may be treated with conization or ablative procedures to remove or destroy the transformation zone. Appropriate intervention for atypical squamous cells of uncertain significance (ASCUS) and LSIL are active areas of research focused on determinants of progression, stability, and regression.

Current clinical care of ASCUS and LSIL increases the vigilance of follow-up and results in colposcopic evaluation for the majority of women with these diagnoses. Evaluation of ASCUS is guided by the cytologic clarification that accompanies the diagnosis: (a) reactive processes are followed with repeat Paps every 6 months until 3 normals; (b) inflammation prompts evaluation for infection, followed by repeat Pap; (c) atrophic changes are treated with topical estrogen, followed by repeat Pap; and (d) ASCUS favoring atypia is evaluated in a fashion comparable to the degree of atypia suggested (i.e., "ASCUS favor LSIL" is evaluated as LSIL). LSIL, in a patient who will be compliant with follow-up and is comfortable with expectant management, can be followed with repeat Paps every 6 months until 3 consecutive negative smears are obtained or progression is noted. Colposcopy and biopsy is preferred for high-risk patients (characteristically broadly defined and not clearly specified) and required for those with immune compromise or prior dysplasia.

As women are screened at younger ages and in larger numbers, and as tests are increasingly sensitive for detecting low-grade changes such as ASCUS and CIN 1, the importance of assessing potential harms of screening becomes clear. The psychological effects of labeling young women with an anxiety-provoking, possibly precancerous condition, and the associated individual, health care system, and societal costs deserve attention. Ideally, screening tools would help guide selection of the intensity of intervention across the spectrum of cervical dysplasia.

For this report, we sought evidence about screening in older age groups and after hysterectomy. We also looked at methods to determine the optimal interval and at the potential contribution of new technologies and HPV testing methods to clinical prevention of cervical cancer. Furthermore, we sought evidence about the cost implications, the population to be screened, and potential harms that follow from screening.

## Prior Recommendations

### US Preventive Services Task Force

The second edition of the Guide to Clinical Preventive Services from the US Preventive Services Task Force gave an "A" to the recommendation of a regular Pap test for all women who are or have been sexually active and who have a cervix.^ 4 ^

The Task Force further stipulated (pg 112):^ 4 ^ There is little evidence that annual screening achieves better outcomes than screening every 3 years ("B" recommendation). The interval for each patient should be recommended by the physician based on risk factors. There is insufficient evidence to recommend for or against an upper age limit for Pap testing, but recommendations can be made on other grounds to discontinue regular testing after age 65 in women who have had regular previous screening in which the testing has been consistently normal ("C" recommendation). Women who have undergone a hysterectomy in which the cervix was removed do not require Pap testing unless the hysterectomy was performed because of cervical cancer or its precursors.

These recommendations were based on limited, although consistent, literature. The use of HPV testing, cervicography, and colposcopy lacked evidence in the literature to support routine use. Recommendations against use were based on other grounds, including poor specificity and costs.

#### Recommendations of Other Groups

Table 2 summarizes the recommendations of 9 selected US organizations and other international groups and health systems with guidelines based on evidence review. We note information on starting age, interval, adaptation of interval for high-risk women, upper age limit for screening, and discontinuation after hysterectomy.

Table 2: Recommendations of Other Groups about Pap Smear for Cervical Cancer Screening

Organization | Test Parameters | Screening Interval | Definition of High Risk | Interval for High Risk | Age to Stop Screening
American College of Obstetricians and Gynecologists, 1995 | Onset of sexual activity or age 18, whichever occurs first | Annual; after 3 years of normal Paps interval may be lengthened | Women with multiple sexual partners or whose male sexual partners have had multiple partners; sexual intercourse at an early age; women whose male sexual partners have had other sexual partners with cervical cancer; women with current or prior HPV or condylomata or both; women with current or prior herpes simplex virus infections; women infected with HIV; women with a history of STDs; women who are immunosuppressed; smokers and abusers of other substances, including alcohol; women who have a history of cervical dysplasia or cervical cancer or endometrial, vaginal, or vulvar cancer; women of lower socioeconomic status | At physician discretion | No end date
American Society of Clinical Pathologists, 1999 | Age 18 or sexually active | Once a year | Cancer, precancerous lesions, a variety of infectious conditions | 3 - 6 months or colposcopy | Continuing for the rest of her life
American College of Preventive Medicine, Practice Guidelines Committee, 1996 | At onset of sexual activity or age 18 if sexual history is unknown | At least 2 initial screening tests 1 year apart; then interval lengthened at discretion of patient and doctor, but not to exceed >3 year interval | Not mentioned | Not mentioned | Age 65, if no abnormal smears in the prior 9 years, unless patient has not been screened adequately
American Academy of Family Physicians, 1996 | Women who have ever had sex and have a cervix | At least every 3 years | Not mentioned | Not mentioned | Not mentioned
Canadian Task Force on Preventive Health Care, 1992 | Women > age 18 who have had sexual intercourse | Two annual screens, then every 3 years | Early onset of sexual intercourse; many sexual partners; sexual partner with many sexual partners | More frequently than 3 years | Until age 69
American Cancer Society, 2000 | Sexually active or Age18 (as prior entries) | Annually until 3 or more consecutive satisfactory examinations, then at physician discretion | Not mentioned | Not mentioned | General cancer check-up recommendations suggest annual exam continue past menopause
Institute for Clinical Systems Improvement, 2000 | Sexually active women younger than age 18 and all women aged 18-64. Omit women who have had a hysterectomy with no residual cervix | 3 consecutive normal smears and no dysplasia within 5 years, then less frequently, but at least every 3 years | Mandelblatt Risk Factor Table of Relative Risk | Annually until no longer show dysplasia within 5 years | Age 65
UK National Health Service Cancer Screening Progammes, 1999 | Age 20. Omit women who have had a total hysterectomy for nonmalignant reasons | At least every 5 years (free cervical smear test) | Certain types of HVP; women with many sexual partners or whose partner has had many partners; long-term use of the pill; women who smoke | Not mentioned | Age 64
Australian National Cervical Screening Program, 1998 | Women who have ever been sexually active beginning at age 18-20 | Every 2 years | Not mentioned | Not mentioned | Age 70 with 2 normal Paps in prior 5 years
New Zealand National Cervical Screening Programme | Women who have ever had intercourse beginning at age 20. Women who have had a total hysterectomy for a benign condition do not require further screening | Every 3 years, except if > 5 years since last or if first smear, then repeat in 1 year's time | Sexual behavior, smoking, hormonal or contraceptive use Immunocompromised women | More frequent screening is not recommended for women possibly at higher risk of cervical cancer as there is no evidence that such women have a shorter duration of the preinvasive stage. Immunocompromised women should be screened annually. | Age 70

Intervals range from 2 to 5 years, in some cases with modification for individual risk and in some cases irrespective of risk. The most commonly advised screening interval is 3 years after a specified number of qualifying prior normal smears.

Six of the 9 groups suggest discontinuation among older women with prior normal screening history: The UK National Health Service Cancer Screening Programmes at 64; the American College of Preventive Medicine and the Institute for Clinical Systems Improvement at 65; the Canadian Task Force on Preventive Health Care at 69; and the National Cervical Cancer Screening Programs of Australia and New Zealand at age 70. Three specifically mention discontinuing testing after hysterectomy for benign disease.

No guidelines specifically address the utility or advisability of using new cytology technologies or HPV testing for screening or triage, within a screening system, except in noting that HPV infection is a high-risk factor that may guide choice of interval.

## Analytic Framework and Key Questions

The RTI-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC), together with members of the USPSTF and other clinical and methodologic experts (see Appendix A), sought to update specific topics in the area of cervical cancer screening that have evolved rapidly in the past 5 years. This systematic evidence review (SER) updates Chapter 9 (pages 105-117) of the second Guide to Clinical Preventive Services.^ 4 ^

### Analytic Framework

Conceptualizing approaches to cervical cancer screening in primary care practice requires an analytic framework. Our framework (Figure 2) is not intended to provide etiologic detail; rather, it depicts the relationship between the progression of disease and the potential points of intervention to prevent morbidity and mortality. These potential points of intervention provide the rationale for the questions undertaken in this systematic review.

Figure 2. Screening for Cervical Cancer: Analytic Framework

The pathway starts with women potentially eligible for screening. We have conceptualized screening as a process that may have more than one component. For example, a woman presenting for care may have her individual risk for cervical cancer assessed based on her past sexual history, medical history, and prior Pap test results. Using that information, clinicians determine the need for a Pap test. If a Pap test is done, the specimen may be prepared by conventional methods or new techniques. The cytology specimen may be read in the conventional manner or with pre-screening or re-screening by computer-assisted methods. Other screening studies, such as HPV testing, may be incorporated before a woman is determined to have normal or abnormal screening results.

We have denoted the combination of screening components in Figure 2 the "screening strategy." Key Questions 2 and 3 (see below) focus on the role of specific components within a cervical cancer screening strategy.

In this analytic framework, women with normal findings at completion of a screening strategy return to the routine screening group. Women with abnormal screening tests progress to further evaluation. Evaluation may fail to identify any abnormalities (false-positive screening test results) or result in the diagnosis of cervical dysplasia or cancer. Among those who are diagnosed with an abnormality, the severity of dysplasia or stage of cancer is the primary determinant of treatment options and morbidity and mortality risk. The success of a screening strategy depends on early detection of pathology, which then facilitates early treatment, ultimately resulting in improved length of life, quality of life, or both for women who are screened.

### Key Questions

Our key questions are provided below. They appear in Figure 2 as Key Q1, Key Q2, and Key Q3 above the related arrows, which indicate steps in the prevention process and disease progression.

- Key Question 1: Who should be screened for cervical cancer and how often?

In developing the work plan for this SER, we specified this question broadly to prompt discussion of what focus would most contribute to guiding screening in primary care practice. We considered a range of potential topics including age at initiation of screening, need for screening among lesbian women, screening recommendations for women with HIV infection, interval of screening in the general population, screening after hysterectomy, and screening among older women including the relationship between aging and interval. Practical limitations required a narrow focus. Ultimately we concurred that our work would be best focused on the screening needs of older women and on screening after hysterectomy. As a result, we restricted our examination to the evidence about the cervical cancer screening needs of older women who have had a hysterectomy.

Specifically, we asked what are the outcomes (benefits, harms, and costs) associated with screening:

1A. Among women age 65 and older?

1B. Among women who have had a hysterectomy?

Only Key Question 1A is focused on older age, interval among older women, and screening outcomes. The remainder of the entire SER applies to all women irrespective of age. For instance, 1B addresses screening among all women who have had a hysterectomy.

- Key Question 2: To what extent do new methods for preparing or evaluating cervical cytology improve diagnostic yield compared to conventional methods? At what cost (harms and economic)?
- Key Question 3: What is the role of HPV testing in cervical cancer screening strategies? Specifically: 3A. What are the benefits, harms, and costs of using HPV testing as a screening test, or of incorporating HPV testing at the time of the screening Pap test, compared with not testing for HPV? 3B. What are the benefits, harms, and costs of using HPV testing as part of a screening strategy to determine which women with an abnormal Pap test should receive further evaluation?

### Relevant Outcomes

Incidence of cervical cancer, severity of disease at the time of diagnosis, and cervical cancer mortality are relevant to all questions. However, no trials have been conducted to evaluate the effectiveness of cervical cancer screening systems for improving these outcomes. Given the rarity of cervical carcinoma among women who receive any screening, much of this literature examines surrogate endpoints such as the diagnosis of dysplasia by colposcopy and/or cervical biopsies. The outcomes we have been able to assess were determined by the content of the literature. Outcome(s) of interest were tailored to the related key questions in the following fashion.

Outcomes for Key Question 1A and 1B, which address candidates for screening, include diagnosis of dysplasia, severity of dysplasia, progression of dysplasia, diagnosis of carcinoma, stage at diagnosis, and mortality. We retained cost data, if relevant to care in the United States, for background information. We also sought harms related to screening.

For Key Questions 2 and 3, which examine the test characteristics of new methods of preparing and evaluating cervical cytology and the contribution of HPV testing, the relevant outcomes include sensitivity, specificity, positive and negative predictive value, and diagnostic yield when compared to a gold standard. The standard used and the quality of evaluation of normal screening results both vary. Much of this literature is limited by failure to apply the gold standard evaluation to normal subjects, which precludes definitive assessment of specificity. We sought to evaluate the influence of these tools on the diagnoses and features listed above for Key Question 1, and we retained literature relevant to US costs for background.

Chapter II provides an overview of our methods for producing the SER. Chapter III presents the results of our literature search and synthesis organized by the key questions. We discuss the results and the limitations of the literature in Chapter IV with attention to ramifications for future research. Appendix A contains acknowledgments, Appendix B provides additional detail about our methods, and Appendix C contains the evidence tables developed from the literature synthesis.