# Appendix C. Evidence Tables

## Glossary of terms

Appendix C Evidence Tables

AGCUS | Atypical Glandular Cells of Unknown Significance
AmInd | American Indian
ASCUS | Atypical Squamous Cells Of Unknown Significance
CA | Cancer
CI | Confidence Interval
CIN | Cervical Intraepithelial Neoplasia
CIS | Carcinoma In Situ
CPI | Clinical Position Imaging
DNA | Deoxyribonucleic Acid
Denom | Denominator
EC | European Community
EPC | Evidence-based Practice Center
FDA | Food and Drug Administration
FN | False Negative
FPR | False Positive Rate
GS | Gold Standard
HC | Hybrid Capture
HC I | Hybrid Capture, First Generation
HC II | Hybrid Capture - Second Generation
HCT | Hybrid Capture Table
Hisp | Hispanic
HPV | Human Papilloma Virus
HSIL | High-Grade Squamous Intraepithelial Lesion
Hx | History
LA | Louisiana
LEEP | Loop Electrosurgical Excision Procedure
LSIL | Low-Grade Sqamous Intraephithelial Lesion
NBCS | National Birth Center Study
NPV | Negative Predictive Value
NS | Not Specified - Not Statistically Significant
OR | Odds Ratio
PCR | Polymerase Chain Reaction
PPV | Positive Predictive Value
PY^®^ | Per year
QC | Quality Check
Ref. Std. | Reference Standard
RR | Relative Risk
SCC | Squamous Cell Carcinoma
SE | Sensitivity
SER | Systematic Evidence Review
SIL | Squamous Intraepithelial Lesion
S/P | Status Post
SP | Specificity
TPR | True Positive Rate
UICC | Union Internationale Contre le Cancer
UK | United Kingdom
UKN | Unknown
VAIN | Vaginal Intraepithelial Neoplasia
WI | Wisconsin
WVC | Wart Virus Changes
YOA | Years Of Age

Evidence Table 1A. Screening Among Older WomenAppendix CEvidence Tables

Source: Author, Year | Study Design & Characteristics | Stated Objective(s) | Location & Time Period | Data Source(s) | Participants | Screening Program | Outcomes & Measures | Relevant Results | Quality Consideration
Cecchini et al., 1995^ 41 ^ | Population-based, retrospective cohort | To investigate the detection rate of CIN3 in previously unscreened women, in order to reveal trends over time in the prevalence of CIN3 | Florence, Italy 1973-1992 | Cervical cancer screening database; centralized colposcopy and pathology services | N = 287,295 Pap smears Age 20-60 at first screening or first screening within 10 years | N/A (identified cases at entry into screening) | Primary outcome = histologically proven CIN3 (n=648) | AGE: Within the age groups from 30-54 age/cohort specific rates of CIN 3 are increasing over secular time. Patterns are variable among older age groups over time. Recent rates by age: | Denom=2 Attrition=DNA Indications=0 (DNA) Interval=0 DNA Age=2 Relevance=0.5 Standard=2 Score=6.5 Grade=Poor
  Age 20-24 | 1.58 cases/1000py
  25-9 | 2.51
  30-4 | 4.94
  35-9 | 4.01
  40-4 | 4.29
  45-9 | 3.40
  50-4 | 3.90
  55-9 | 1.88
Gustafsson et al.,1995^ 81 ^ | Population-based, retrospective cohort | To estimate the efficiency of detecting cancer in situ in cytologic screening for cervical cancer at different ages with emphasis on women older than 50 | Uppsala County, Sweden 1969-1988 | Cervical cancer screening and pathology database | N = 118,890 women with 466,259 Pap smears in registry before diagnosis of cancer in situ or invasive cancer | Not specified | Primary outcome = cancer in situ n=1076 | AGE: 17% of smears from women Z > 50 yoa. CIS among > 50 was 4.6%. Therefore detection ratio per thousand smears of 0.63. Contrasted with peak detection ratio of 3.3 for women ages 25-35; and combined ratio for those under 50 of 2.6. AGE & SCREENING HISTORY: (Subanalysis - n = 5,893) Among women with 3 normal smears between 41 and 49, 60 (1%) had Class 3-5 smear after 50, including 4 CIS, 3 invasive cancers and 2 adenocarcinomas | Denom=2 Attrition=1 Indications=2 Interval=1 Age=2 Relevance=1 Standard=2 Score=11 Grade=Fair
Kainz et al., 1995^ 34 ^ | Retrospective cohort | To assess the incidence of CIN detected by cervical smears among women of different ages and to compare two quintennia | Vienna, Austria 1980-1989 | Computerizedrecords from a single cytology lab. Included Pap smears were obtained by gynecologists who used only this cytology lab | N = 12,604 non-pregnant women with 2 Paps within 350-380 days; negative cytology on 1st smear. Women with history of "inflammatory smears" or CIN excluded | Annual advised | Primary outcome = CIN 1-3 on cytology (Histology gold standard for quality control stated, not described) | AGE: Incidence of CIN 1-3 | Denom=2 Attrition=2 Indications=2 Interval=2 Age=1 Relevance=1 Standard=1+ Score=11 Grade=Fair
  Age | 1980-84 | 1985-89 | RR (95%CI)
  < 20 | 4/697 | 4/593 | 1.2(0.3,4.7)
  21-30 | 12/2570 | 34/2102 | 3.5(1.9,6.5)
  31-40 | 5/1737 | 11/1150 | 3.3(1,2, 9.0)
  >41 | 8/1694 | 2/2061 | 0.2(0.1,0.8)
Forsmo et al., 1996^ 37 ^ | Retrospective cohort | To examine...risk of cancer and CIN in Pap smears from women without previously reported positive smears | Finnmark & Troms counties, Norway 1988-1990 | Computerized records from a single cytology lab | N = 40,536 women with 58,271 Paps; no prior abnormal cytology including smears with evidence of HPV or Herpes virus Age 13-100, mean age: 36 | No systematic screening program in place; centralized recall for follow-up of abnormal Paps only | Primary outcome = CIN 1-cancer on cytology (No histology based data) | AGE: Incidence ORs* CIN 3 & Cancer Among Older * Adjusted for time since last smear ˆ Adjusted for age | Denom=2 Attrition=2 Indications=2 Interval=2 Age=2 Relevance=1 Standard=0 Score=11 Grade=Fair
  | Cases CIN 1-2 | Cases CIN 3 | Total N
  < 19 | 43 | 1 | 4,962
  20-29 | 203 | 21 | 18,531
  30-39 | 96 | 27 | 13,761
  40-49 | 43 | 13 | 9,955
  50-59 | 22 | 12 | 5,370
  60-69 | 10 | 7 | 3,568
  70 | 10 | 9 | 2,124
  Women | (95%CI)
  Age | CIN 3 | Cancer
  50-59 | 1.0 (ref) | 1.0 (ref)
  60-69 | 0.6 (0.2, 1.4) | 2.5 (0.7, 9.7)
  > 70 | 0.8 (0.2, 0.8) | 1.9 (0.4, 8.1)
  INTERVAL: (months) | ORˆ (95%CI)
  First | 1.0 (ref) | 1.0 (ref)
  12 | 0.1 (0.0, 0.7) | ---
  13-35 | 0.04 (0.0, 0.2) | 0.04 (0.0, 0.3)
  36-59 | 0.12 (0.0, 0.4) | 0.1 (0.1, 0.8)
  60 | 0.26 (0.1, 0.7) | 0.5 (0.2, 1.6)
Mitchell et al., 1996^ 82 ^ | 1) Prospective Cohort; 2) Case series | 1) To determine the annual rate of interval squamous cancer of the cervix after a negative [Pap test]; and 2) To evaluate the proportion of women with cervical cancer who received negative reports during the three years before the cancer diagnosis | Victoria province, Australia 1990-1993 | Centralized cytology registry and cancer registry | 1) 368,051 women with normal Pap in 1990 Age <70 2) 233 women with new diagnosis of cervical cancer in 1993 (all ages) | Recommends screening every 2 yrs after a negative Pap, stopping at 70 | Primary outcome = microinvasive and invasive cervical cancer as documented by cancer registry which includes histology | AGE: INTERVAL: Of 167 women with diagnosis of squamous cell cancer, 34 (20%) had a negative Pap report within the preceding 3 years | Denom=2 Attrition=1 Indications=0 Interval=2 Age=0 Relevance=1 Standard=2 Score=8 Grade=Poor
  Interval cancer rate: | | (95%CI)
  Age <35: | 2.54/100,000 | (1.5, 4.3)
  Ages 35-69: | 2.53/100,000 | (1,5, 4.3)
Cruickshank et al.,1997^ 39 ^ | Retrospective Birth Cohort | To determine the pattern of abnormal cervical cytology in women aged 50 to 60 years and to determine whether the development of cervical neoplasia in this age group is confined to women who have been inadequately screened | Grampian region, UK 1989-1994 | Centralized cytology registry | N = 30,527 women 25,216 hysterectomy Born between 10/2/33 & 10/1/44 (i.e. 50-60 at time of analysis); and without hysterectomy | Call and recall screening system to achieve screening every 3 years between ages 20-60 More than 93% of population has been screened at least once | Primary outcome = "non-negative smear" defined as borderline atypia or greater n= 229 Secondary outcome = Histologic diagnoses | AGE Histology among 164 women who had biopsy for non-negative smear Of 8 cancers, 1 first screened after age 50; 3 had prior known abnormal smears; 2 had their two prior smears at intervals >5 yrs; 1 between 4-5 years. None were found who had interval < 3 years with normal smears | Denom=2 Attrition=2 Indications=2 Interval=2 Age=1 Relevance=1 Standard=1 Score=11 Grade=Fair
  | Non-neg. Smear | N Screened | % Non-neg
  50-53 | 161 | 10,365 | 1.4
  54-57 | 54 | 8,913 | 0.6
  58-60 | 14 | 6,469 | 0.2
  Negative | 27
  Viral changes only | 16
  CIN 1 | 13
  CIN 2 | 19
  CIN 3 | 70
  Micro-invasive* | 4
  Invasive cancer* | 4
  Clinically detected | 7
  Other | 4
  * Screen detected
Gram et al.,1998^ 35 ^ | Prospective cohort | To investigate the influence of screening history on the diagnosis of CIN 3 and cervical cancer in an opportunistic screening program | Troms and Finnmarker counties, Norway 1980-1989 | Computerizedrecords from a single cytology lab | N = 41,212 women with negative Pap at entry Born 1920-69; no CIN or cervical cancer hx; no hx of cervical biopsy | No systematic screening program in place; centralized recall for follow-up of abnormal Paps only | Primary outcome = CIN 3 or cervical cancer 396 incident in 175,673 person yrs | AGE: Incidence rate for CIN 3 and cancer was highest among women aged 25-29 and decreased with age thereafter: INTERVAL: Age-Adjusted Risk of CIN III/Cancer | Denom=2 Attrition=0 Indications=2 Interval=2 Age=2 Relevance=1 Standard=1 Score=10 Grade=Fair
  Age | Person | Cases
  | Years | 10,000 PYR
  20-24 | 33,663 | 68
  25-29 | 34,349 | 136
  30-34 | 27,325 | 87
  35-39 | 27,325 | 44
  > 40 | 48,666 | 61
  Years | RR | (95% CI)
  < 1 | 1.0
  1 | 1.5 | (1.2, 2.0)
  2 | 2.4 | (1.8, 3.3)
  3+ | 12.2 | (9.2, 16.3)
Lawson et al., 1998^ 40 ^ | Prospective Cohort | To evaluate the results of cervical cytology screening in the National Breast and Cervical Cancer Early Detection Program (NBCCEDP) | US (sites in 22 states and 5 native tribal programs) 10/1/91-6/30/95 | Prospective data collection as part of NBCCEDP | N = 312,858 women with 407,246 Paps Services intended for low-income women Black, non-Hisp 10.3% | | Primary Outcome = histologic diagnoses of CIN 2,3, CIS and invasive cancer (all cases with histology from CIN 1, up reported) Secondary outcome = cytology findings | AGE: First Screening Cycle Rates* of histology-proven diagnoses Second Screening Cycle Rates* of histology-proven diagnoses * Rates = diagnoses per 1000 Pap smears | Denom=2 Attrition=0 Indications=1 Interval=0 Age=2 Relevance=2 Standard=0 Score=7 Grade=Fair
  Age
  40-49 | 25.2%
  50-64 | 24.9%
  > 65 | 7.6%
  Hisp | 21.2%
  Asian | 2.3%
  AmInd | 10.4%
  | CIN 2 | CIN 3/CIS
  Invasive
  < 30 | 11.0 | 7.9 | 0.1
  30-39 | 4.9 | 6.7 | 0.4
  40-49 | 2.0 | 3.2 | 0.5
  50-64 | 0.9 | 1.7 | 0.6
  > 65 | 0.5 | 1.4 | 0.3
  | CIN 2 | CIN 3/CIS | Invasive
  < 30 | 7.6 | 4.2 | 0.1
  30-39 | 3.8 | 4.1 | 0.4
  40-49 | 1.7 | 1.3 | 0.2
  50-64 | 0.7 | 1.2 | 0.1
  > 65 | 0.8 | 0.7 | 0.0
  | First test | Subsequent
  Age | % Abnormal | %Abnormal
  < 30 | 8.2 | 7.4
  30-39 | 4.3 | 4.2
  40-49 | 2.3 | 2.3
  50-64 | 1.4 | 1.5
  > 65 | 1.0 | 1.0
Sigurdson et al., 1999^ 43 ^ | Retrospective Cohort | To evaluate the UICC and EC recommendations regarding target age group and screening interval | Iceland 1966-1995 | Records of the national cervical cancer screening program | N = not defined (only rates given) | National screening program with call and recall of ages 25-69 (1970-1987) now 20-69 (began 1988) for screening q2-3 years | Primary outcome = histologically proven lesions Secondary outcome = moderate to high grade smears | INTERVAL: Cumulative rate of histologically verified lesions among women referred for colposcopy rises from 10% of those referred within 2 yrs of a normal Pap to 70% of those referred within 5 yrs. AGE: After age 60, the rate of moderate to high-grade dysplasia among women without prior screening = 16/1000; 5.7/1000 if 1-4 prior screens; 2.8 if > 5 | Denom=2 Attrition=1 Indications=1 Interval=2 Age=2 Relevance=1 Standard=2 Score=11 Grade=Fair
Sawaya et al., 2000^ 26 ^ | Prospective cohort | To compare cervical screening outcomes associated with age and screening intervals: 1, 2, and 3 years | US 1991-1998 | Prospective data collection as part of National Breast & Cervical Cancer Early Detection Program | N = 128,805 women with initial normal Pap and another within 36 months (excludes those with glandular cell abnormalities) Black, non-Hisp 13.4% | | Primary outcome = high grade SIL or worse on cytology Secondary outcome = other cytologic abnormality Second smears | AGE: 2nd screening results INTERVAL: Age-adjusted incidence per 10,000 women | Denom=2 Attrition=2 Indications=1 Interval=2 Age=2 Relevance=2 Standard=0 Score=11 Grade=Fair
  Age
  <30 | 9.5%
  30-49 | 41.6%
  50-64 | 36.8%
  > 65 | 12.1%
  White | 57.2%
  Hisp | 17.6%
  Asian | 2.4%
  AmInd | 8.5%
  results: | (%)
  Benign | 94.4
  ASCUS | 3.4
  LSIL | 0.9
  HSIL | 0.2
  Cancer | 0.0
  | LSIL (%) | HSIL (%) | SCCA (%)
  < 30 | 389 (3.2) | 80 (0.7) | 1 (0.01)
  30-49 | 523 (1.0) | 111 (0.2) | 5 (0.01)
  50-64 | 186 (0.4) | 67 (0.14) | 4 (0.01)
  > 65 | 42 (0.3) | 13 (0.08) | 3 (0.02)
  Time from normal | ASCUS | LSIL | HSIL +
  9-12 mos | 377 | 107 | 25
  13-24 | 373 | 125 | 29
  25-36 | 415 | 141 | 33
  P (trend) | 0.36 | 0.01 | 0.42
Sawaya et al., 2000^ 36 ^ | Prospective cohort | To determine differences in incidence of high-grade cytology following 1, 2, or 3 or more normal smears | US 1991-1999 | Prospective data collection as part of National Breast & Cervical Cancer Early Detection Program | N = 128,805 women with initial normal Pap and at least another in the timeframe Mean age = 49.9 13.3 yrs | | Primary outcome = HSIL+ on cytology | AGE: Incidence of abnormalities within 36 month following 1, 2, or 3 consecutive normal smears PRIOR HISTORY: Age& interval adjusted relative risk | Denom=2 Attrition=2 Indications=1 Interval=2 Age=2 Relevance=2 Standard=0 Score=11 Grade=Fair
  | | LSIL % | HSIL+ %
  <30 | (1) | 3.47 | 0.65
  | (2) | 2.33 | 0.67
  | (3) | 1.70 | 0.62
  30-39 | | 1.48 | 0.44
  | | 0.90 | 0.11
  | | 0.40 | 0.11
  40-49 | | 0.85 | 0.18
  | | 0.75 | 0.16
  | | 0.40 | 0.02
  50-59 | | 0.49 | 0.19
  | | 0.31 | 0.10
  | | 0.22 | 0.06
  > 60 | | 0.35 | 0.12
  | | 0.30 | 0.09
  | | 0.14 | 0.02
  #prior normals | RR/1,000 women | (95%CI)
  1 | 23.6
  2 | 16.5 | (12.0-22.4)
  3+ | 7.6 | (4.0-14.2)
Sawaya et al., 2000^ 44 ^ | Prospective cohort | To determine the positive predictive value of cervical smears in previously screened post-menopausal women and to determine the effect of oral estrogen plus progestin on incident cervical cytologic abnormalities | US study 20 clinics Date Not Specified | Data collected prospectively for the Heart & Estrogen-progestin Replacement Study (HERS) a randomized, placebo controlled trial of hormone replacement | N = 2,561 women with normal baseline smears Mean age: 66 Nonwhite: ~ 10% | Annual screening during an average of 4 years of study participation | Primary outcome = "new cytologic abnormality" Defined as ASCUS, AGCUS, LSIL, or HSIL OUTCOME RATE Secondary outcome Results of evaluation for abnormal Pap | Timing of abnormal smears after prior normal * Endometrial hyperplasia without atypia | Denom=2 Attrition=2 Indications=2 Interval=1 Age=0 Relevance=2 Standard=1 Score=10 Grade=Fair
  1 year later | 78/2561 (3.0%)
  2 years later | 32/2346 (1.4%)
  Total | 110 abnormals
  | | | Final Diagnosis
  | NL | LSIL | HSIL | Endo* | UKN
  Cytology
  ASCUS | 66 | 2 | 1 | 1 | 4
  AGCUS | 20 | 2 | --- | --- | 1
  LSIL | 8 | 2 | --- | --- | 2
  HSIL | --- | --- | 1 | --- | ---
  Total | 94 | 6 | 2 | 1 | 7

Evidence Table 1B. Pap Testing After HysterectomyAppendix CEvidence Tables

Source: Author, Year | Study Design | Stated Objective(s) | Location & Time Period | Data Source(s) | Participants | Screening Program | Outcomes & Measures | Relevant Results | Quality Considerations
Fox et al., 1999^ 47 ^ | 1. Population-based cross sectional study 2. Nested case-control study | To determine the risk of cytologic abnormality on a screening Pap for women >= 50 years with and without a uterine cervix | Dane County, WI 1/1/95-8/15/95 | Regional cytology center database; physician-reported hysterectomy status | N=21,152 Pap smears (cross sectional study) 5330 s/p hysterectomy N=173 nested case-control study Age >= 50 years; women being followed up for previous abnormality or with bleeding/discharge excluded Population base is 97% white | Not stated hysterectomy | Primary outcome = abnormal Pap, defined as ASCUS, dysplasia (low and high grade SIL) or carcinoma as determined by cytopathologist (n=173) and reported by hysterectomy status For case-control study, primary exposure= hysterectomy status | Results from cross-sectional study: Rates of abnormality among women From case-control study: Odds ratios for an abnormal screening Pap=0.09 (95% CI=0.02-0.24) for those with hysterectomy versus those without | Grade=Fair
  Among all | 8.2/1000
  Among those with hysterectomy
  | 1.7/1000
  Among those without hysterectomy
  | 10.4/1000
Pearce, et al., 1996^ 48 ^ | Retrospective cohort study | To determine the prevalence and clinical importance of abnormal vaginal Pap smears in a population of women with hysterectomy | New Orleans, LA, 1/1/92-12/31/94 | Charity Hospital cervical screening database; review of medical records for diagnostic test results following abnormal Paps | N=9610 smears among women with hysterectomy and without history of cervical, vaginal, ovarian, fallopian tube or uterine cancer, or CIN III Mean age=52 83% black race | Not stated | Primary outcome= abnormal Pap, defined as ASCUS, LGSIL, HGSIL, or squamous-cell carcinoma; classified by two independent cytopathologists following review 27/79 women with abnormal results verified with colposcopy | 27/79 women with abnormal Paps referred for colposcopy, 5/27 found to have biopsy-proved VAIN on colposcopy (PPV of Pap for VAIN detection 6.3%, 95% CI 3.1 to 18.0); no biopsy proved cases of carcinoma | Grade=Fair

Evidence Table 2. New Methods for Preparing or Evaluating Cervical CytologyAppendix CEvidence Tables

Source: Author, Year | Study Design & Characteristics | Interventions | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations* | Quality Considerations
AutoPap
Colgan et al., 1995^ 83 ^ | Prospective blinded comparison | AutoPap 300 QC rescreening vs. manual rescreening among smears initially categorized as negative | Ontario, Canada Time period not specified Independent service cytopathology laboratory | 3487 smears screened manually as negative | Blind interpretation No. of FN/No. rescreened No. of FN with AutoPap/total FN GS: cytology (independent panel) applied to discrepant cases | AutoPap 20% review rate Yield: (ASCUS+) = 57/3487 (1.6%) (LSIL+) = 10/3487 (0.29%) FN (AutoPap)/FN total (ASCUS+) = 57/86 (66.3%) FN (AutoPap)/total (LSIL+) = 10/13 (76.9%) | Quality Score=6 Ref. Std: 0 Blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 0
Patten et al., 1997b^ 84 ^ | Diagnostic test evaluation No reference standard. No histological verification. | AutoPap 300 QC vs. initial reading | US 1997 Commercial or hospital/academic laboratories | Current archive sensitivity: 2339 Pap smears including positives and negative controls; Historic sensitivity study 3028 Pap smears comprising positiveand negative controls | No. of FN detected by AutoPap/total FN (estimate of sensitivity) | AutoPap 10% review rate: Est. Se (ASCUS+) = 67/203 (33%) Est. Se (LSIL+) = 18/32 (56%) AutoPap 20% review rate: Est. Se (ASCUS+) = 103/203 (51%) Est. Se (LSIL+) = 21/32 (66%) No data on specificity of AutoPap rescreen | Quality Score=4 Ref. Std: 0 Blind: 2 Verification: 0 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 0
Lee et al., 1998^ 85 ^ | Diagnostic test evaluation | AutoPap primary screening system | 9 cytopathology laboratories c. 1997 | 683 Pap smears (264 normal) | Sensitivity and workload reduction GS: cytology (independent panel) | Se (ASCUS+) = 330/357 (92.4%) Se (LSIL+) = 195/199 (98%) Feasibility study of location-guided screening. No results for slides initially read as normal. | Quality Score=6 Ref. Std: 0 Blind: 2 Verification: 2 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 0
Stevens et al., 1997^ 86 ^ | Prospective comparison | AutoPap 300 QC vs. random manual rescreening | Australia 1995-1995 Cytology laboratory | 1840 Pap smears initially read as "normal" | No. of FN detected by AutoPap/total FN (estimated sensitivity) GS: cytology (independent panel review of discrepant cases) | AutoPap: Est. Se: 30% review rate: 4/7 (52%) 20% review rate 3/7 (43%) 10% manual review: Est. Se 0/7 = 0% | Quality Score=6 Ref. Std: 0 Blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 0
Wilbur et al., 1996^ 87 ^ | Diagnostic test evaluation | AutoPap 300 QC 10% or 20% rescreening rate | New York Commercial and academic cytopathology laboratories | 86 cases of known HSIL+ from archives of two labs | Sensitivity of AutoPap to detect known HSIL+ GS: histology | In 86 biopsy-positive cases with cytological diagnosis of HSIL+, AutoPap selected 66 (77%) at 10% review fraction and 74 (86%) at 20% review fraction Limitation: not rescreening use | Quality Score=4 Ref. Std: 2 Blind: 0 Verification: 1 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: 0
Wilbur et al., 1998^ 88 ^ | Prospective two-armed comparison | AutoPap primary screening system vs. manual screening | Time period not specified 5 commercial cytopathology laboratories | 25,124 Pap smear slides, excluding "high-risk" slides | Estimated sensitivity Relative TPR Relative FPR GS: cytology (independent panel review of discrepant cases). No histological verification. | Est Se (ASCUS+) = 1199/1397 (85.8%) Est Se (LSIL+) = 321/348 (92.2%) Relative TPR (AutoPap/conv) = 1199/1106 = 1.08 Relative FPR (AutoPap/conv) = 1123/1322 = 0.85 Limitation: results not reported for performance of AutoPap System on slides with manual screen witin normal limits. AutoPap system uses a different algorithm from AutoPap 300 QC | Quality Score=6 Ref. Std: 0 Blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 0
Wilbur et al., 1999^ 89 ^ | Prospective two-armed comparison of conventional manual cytologic review with 10% rescreening | Rescreen of conventional manual screening of Pap using AutoPap | Five commercial laboratory sites Time period not given | 25,124 slides, excluding "high risk" slides | Pap results: Bethesda method Reference standard: HGSIL and above | Prevalence: HSIL+ = 70/25,124=0.28% AutoPap: Se (ASCUS+, HSIL+)=86% Se (LSIL+, HSIL+)=92% Se (HSIL+, HSIL+)=97% Manual reading: Se (ASCUS+, HSIL+)=79% Se (LSIL+, HSIL+)=86% Se (HSIL+, HSIL+)=93% Specificity cannot be calculated | Quality Score= 5 Ref. Std:0 Blind:2 Verification:0 Consecutive:0 Spectrum:1 Publication:1 Industry:1
Papnet
Ashfaq et al., 1995^ 90 ^ | Diagnostic test evaluation Prospective validation of Papnet rescreening | Papnet rescreening vs. manual rescreening among samples initially categorized as negative | Dallas, TX Time period not specified Academic medical center | 2238 smears screened manually as negative. No patients with known prior dysplasia, radiation or chemo-therapy, post-menopausal vaginal bleeding; symptomatic | No. of FN/ No rescreened GS: cytology (single independent cytopathologist) only for slides called unsatisfactory or atypical on Papnet review | Papnet rescreening resulted in 91/2238 "review," 45/2238 "inadequate," 2102/2238 negative (94%) Manual rescreen of 91 atypical cases found: 5/91 ASCUS or LSIL. 86/91 negative (20% BCC) Detection rate 0.2% Manual rescreen of 45 inadequate found: 36/45 negative, 9 truly unsatisfactory | Quality Score=5 Ref. Std: 0 Blind: 0 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Slagel et al., 1995^ 91 ^ | Diagnostic test evaluation | Papnet screening | Iowa City, IA 1990 | 500 previously screened Pap smears; 435 of which had been screened previously as normal | No. of FN/No. rescreened GS: cytology (single independent pathologist). Discrepant cases reviewed | FN yield: 15/450 (3.3%) | Quality Score=7 Ref. Std: 0 Blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Farnsworth et al., 1996^ 92 ^ | Prospective, blind comparison | Papnet rescreening vs. manual rescreening | Sydney, Australia 1/95-9/95 Large cytopathology laboratory | 54,658 Pap smears initially read as normal, and 1022 Pap smears classified as abnormal | No. of FN/No. rescreened GS: cytology (single cytopathologist). Histological validation for small subset of Papnet positive smears | Papnet identified 266/54658 = 0.49% (32 ASCUS, 217 LSIL, 17 HSIL) Papnet detected all 122 HSIL and ICC, but failed to detect 112 (14 ASCUS, 98 LSIL) of 1022 known positive smears | Quality Score=7 Ref. Std: 0 Blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Ashfaq et al., 1997^ 93 ^ | Diagnostic test evaluation Prospective, blind comparison of Papnet | Papnet (pre-) screening vs. manual screening diagnosis | Dallas, TX Time period not specified Academic medical center | 5170 consecutive Pap smears | Sensitivity and specificity to known abnormals GS: cytology (single independent cytopathologist) for discrepant cases only | Papnet: Se 86.1% Sp (ASCUS+) = 82% Sp (LSIL+) = 93.6% Manual screening: Se = 77.3% Sp (ASCUS+) = 77.3% Sp (LSIL+) = 92.5% Performance among manually screened negative slides not reported | Quality Score=7 Ref. Std: 0 Blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Duggan and Brasher, 1997^ 94 ^ | Prospective, blind comparison of Papnet vs. manual screening | Papnet pre-screening vs. manual screening | Alberta, Canada 3-month period in 1995 Pathology laboratory | 5037 consecutive Pap tests for cervical cancer screening (smears from colposcopy or gynecology-oncology clinics excluded), 4574 of which were negative on manual screening | No. of FN/No. rescreened GS: cytology (panel). Verification of discrepant cases | Papnet: 17/4574 = 0.37% | Quality Score=7 Ref. Std: 0 Blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Halford et al., 1997^ 95 ^ | Prospective comparison of Papnet rescreening vs. historical rapid rescreening No independent cytology panel. No histological verification | Papnet rescreening vs. rapid manual rescreening | Australia Time period not specified | 1000 negative smears seeded with 20 "difficult" cases | No. of FN/No. rescreened Sensitivity to known abnormals | Results not given for false negative detection Se(known abn ASCUS+) 19/20 (95%) Rapid manual rescreening Se (known abn ASCUS+) = 9/20 (45%) | Quality Score=2 Ref. Std: 0 Blind: 0 Verification: 0 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: 1
Jenny et al., 1997^ 96 ^ | Diagnostic test evaluation | Papnet | Zurich, Switzerland 1988-1994 Private cytopathology laboratory | 1200 smears 516 with histologically proven diagnosis; 29 of which had been manually screened as negative | No. of FN/No. rescreened GS: Histological validation. No validation of test negatives | Papnet rescreening: Se(LSIL+) = 26/29 = 89% In primary screening: 2 independent Papnet reviews identified 435 & 469 of 516 (91% & 84%) Manual screening: 403/561 (78.1%) Relative TPR 1.08-1.16 Papnet compared to manual screening | Quality Score=7 Ref. Std: 2 Blind: 2 Verification: 1 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: 1
Kaufman et al., 1998^ 97 ^ | Diagnostic test evaluation, Papnet rescreening compared with colposcope- directed biopsy All subjects verified | Rescreening of conventional Pap smear using Papnet | Texas 1993-1995 | 160 women with colposcopy and biopsy within 1 year of a smear initially reported as ASCUS | Blind interpretation Papnet diagnosis (ASCUS/ AGUS, LSIL, HSIL, Ca) GS: colposcope-directed biopsy (normal, HPV, CIN 1, CIN 2, CIN 3) | Prevalence(CIN1)=69/160=43% Se (LSIL,CIN1)=26/69=38% Sp (LSIL,CIN1)=84/91=92% Prevalence(CIN2/3)=22/160= 14% Se (LSIL,CIN2/3)=9/22=41% Sp (LSIL,CIN2/3)=114/138=83% Limitations: Narrow spectrum of disease (ASCUS/AGUS) | Quality Score=10 Ref. Std: 2 Blind: 2 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 0
Mango and Valente, 1998^ 98 ^ | Diagnostic test evaluation | Papnet rescreening vs. manual rescreening | 1985-1992 Academic cytopathology laboratories | 2293 smears underwent Papnet rescreening; 13761 underwent manual rescreening | No. of FN/No. rescreened GS: cytology (single pathologist). No verification of rescreen negatives. No histological validation | Papnet: FN yield (ASCUS+)142/2293 (6.3%) FN yield (LSIL+) 48/2293 (2.1%) Manual rescreen: FN yield (ASCUS+) 82/13761 (0.6%) FN yield (LSIL+) 36/13761 (0.3%) | Quality Score=4 Ref. Std: 0 Blind: 0 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 0
Mitchell and Medley, 1998^ 99 ^ | Evaluation of Papnet rescreening | Papnet rescreening | Australia 1990-1992 | 19,805 Pap smears with 2 negative manual screens | No. of FN/No. rescreened GS: cytology (panel). No verification of rescreen negatives. Histologic validation of some rescreen positives | FN yield (single cytologist): 212/19805 (1.1%) FN yield (cytology panel): 162/212 (0.82%) FN yield (histology): 14/26 high-grade and 33/102 low-grade abnormalities histologically confirmed | Quality Score=5 Ref. Std: 0 Blind: 0 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
O'Leary et al., 1998^ 100 ^ | Prospective evaluation of Papnet rescreening | Papnet rescreening | Washington, DC 1994-1995 Government pathology organization | 5478 consecutive Pap smears read as normal or benign cell changes on initial and random rescreening | No. FN/No. rescreened GS: cytology (independent panel). Verification of discrepant cases only | Papnet identified 1614 (29%) of slides requiring review; 1166 because no endocervical component was identified. 448 (8% of total) Only 11 cases demonstrated abnormal cells (5 ASCUS, 1 AGUS, 6 LSIL+) 11/5478 (0.2%) | Quality Score=5 Ref. Std: 0 Blind: 0 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Duggan, 2000^ 60 ^ | Diagnostic test evaluation of Papnet system vs. conventional manually read Paps in primary screening Reference standard: consensus by peer review | Rescreen of conventional manual screening Pap results using Papnet | Calgary, Alberta Starting date for slide selection: December 1995 | 2,200 archival slides selected: 2000 normals, 200 abnormals | All Pap results: Bethesda method Reference standard: Negative, ASCUS/AGUS, LSIL, HSIL, Ca | Prevalence (artificially set): LSIL=52/2195=2.4% HSIL=62/2195=2.8% Ca=39/2195=1.8% Se (ASCUS/AGUS, LSIL+)=72.7% Sp (ASCUS/AGUS, LSIL+)=99.4% Se (LSIL, LSIL+)=87.2% Sp (LSIL, LSIL+)=99.9% Se (HSIL, HSIL+)=98.2% Sp (HSIL, HSIL+)=99.9% | Quality Score= 7 Ref. Std:1 Blind:2 Verification:1 Consecutive:0 Spectrum:1 Publication:1 Industry:1
Kok et al., 2000^ 101 ^ | Diagnostic test evaluation of neural network-based screening using Papnet compared to traditional Pap Reference standard: 69 patients with biopsy confirmed carcinoma | Women randomized to receive screening by Papnet (245,527) or traditional Pap (109,104) Collection method: Cytobrush | Netherlands 1992-1997 | Women undergoing routine screening aged 30 to 60 years (194,358), or screening for any other reason (160,373). | All Pap results: abnormal defined as CIN-I or greater Reference standard: biopsy-confirmed squamous cell carcinoma | Prevalence SCC=71/354,631=0.02% Estimated Se (CIN-I by Papnet+, SCC)=90.4% Specificity cannot be calculated No gold standard verification of all test positives and test negatives; specificity cannot be calculated | Quality Score=9 Ref. Std: 2 Blind: 2 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
ThinPrep 2000
Corkill et al., 1997^ 102 ^ | Diagnostic test evaluation Prospective, split sample, double-masked trial. Discrepancies and 5% of test-negatives verified by single independent pathologist only for second group. No histologic verification of test-positives | Conventional Pap vs. ThinPrep. Split sample collected with cytobrush/spatula | Colorado 5/95-6/95 and 3/96-4/96 11 planned parenthood clinics | 462 subjects in first group, 1239 in following group. All patients >18 years, premenopausal, and no history of abnormal Pap | Concordance between ThinPrep and conventional smear; discrepancies and 5% of test-negatives verified by single independent pathologist only for second group | Unable to get estimate of specificity because no test positives verified with histology. ThinPrep more likely to identify slides as abnormal (LSIL+) than conventional smear | Quality Score=3.5 Ref. Std: 0 Blind: 2 Verification: 0 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: .5
Lee et al., 1997^ 103 ^ | Diagnostic test evaluation, conventional Pap vs. ThinPrep ThinPrep clinical trial: 6 centers, prospective, split sample, double-masked trial Discrepancies and 5% of test-negatives verified by single independent pathologist No histologic verification of test-positives | Conventional Pap vs. ThinPrep. Split sample collected with broom device | US 1996 6 sites; 3 community clinics and 3 hospitals | 6747 women, recruited from 6 centers. 3 hospital centers selected for high proportion of high-risk women. 58.9% white, 21.7% black, 13.9 % Hispanic, 2.2% other | Concordance between ThinPrep and conventional smear; discrepancies and 5% of test-negatives verified by single independent pathologist | Unable to get estimate of specificity because no test positives verified with histology. ThinPrep more likely to identify slides as abnormal (ASCUS or LSIL) than conventional smear in screening centers, but not in hospitals | Quality Score=5.5 Ref. Std: 0 Blind: 2 Verification: 1 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: .5
Roberts et al, 1997^ 104 ^ | Diagnostic test evaluation. split sample, ThinPrep vs. conventional Pap Discrepant results reviewed Most of test-positives with HSIL verified. No test negatives verified with histology | Split sample technique with Cervex broom used to prepare both conventional Pap and ThinPrep 2000 | Australia 1996-1997 | 35,560 pairs received from 500 practitioners who chose to offer ThinPrep along with conventional smear. 24% of women undergoing screening pap, and 35% of women needing referral pap had both samples taken | No blind interpretation Conventional smear and ThinPrep thresholds of minor changes/HPV, LSIL, inconclusive abnormality, HSIL, cytologic reference standard for test negatives. Histologic reference standard for those with HSIL or inconclusive results on either conventional smear or ThinPrep | All discrepant results reviewed by independent cytopathologist Most of HSIL and inconclusive results on either ThinPrep or conventional smear had histologic confirmation No test negatives verified, or those with LSIL Relative True Positive rate (ThinPrep)=178/158=1.13 Relative False Positive rate(ThinPrep)=37/33=1.12 | Quality Score=1.5 Ref. Std: 0 Blind: 0 Verification: 0 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: .5
Bolick and Hellman, 1998^ 105 ^ | Diagnostic test evaluation Selection of negative smears uncertain | Conventional Pap (broom-type sampling device or a combination endocervical brush and plastic spatula) vs. ThinPrep | Utah 1996-1997 | 39,408 conventional Paps, and 10,694 ThinPrep specimens, collected concurrently in two patient populations, described only by age | No blind interpretation Pap and ThinPrep specimen with threshold of LSIL GS: histology with threshold of "positive" | Screening test: ThinPrep Prevalence(not specified)= 42/54=78% Se (LSIL,NS)=40/42=95% Sp (LSIL,NS)=7/12=58% Screening test: Pap Prevalence(NS)=67/89=75% Se (LSIL,NS)=57/67=85% Sp (LSIL,NS)=8/22=36% | Quality Score=4 Ref. Std: 2 Blind: 0 Verification: 0 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: 1
Inhorn et al., 1998^ 106 ^ | Diagnostic test evaluation of ThinPrep vs. conventional Pap Cancer specimens from ThinPrep clinical trial, including results from ThinPrep beta and ThinPrep 2000 ThinPrep and conventional smear obtained from known cancer patients, split-sample No disease negatives studied | ThinPrep vs. conventional Pap. Split-sample, obtained with broom device | 5 institutions, gynecologic oncology clinics | 47 patients with known cervical cancer | No blind interpretation Ability of ThinPrep and conventional smear to identify cancerous cells as cancer | Independent reference pathologist only for samples from ThinPrep 2000 study only Study only evaluated cancer patients, therefore unable to estimate specificity ThinPrep identified 21/22 smears as cancer (1 was ASCUS) Conventional smear identified 19/22 as cancer (1 was ASCUS, 2 were unsatisfactory) | Quality Score=3.5 Ref. Std: 2 Blind: 0 Verification: 0 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: .5
Papillo et al., 1998^ 107 ^ | Diagnostic test evaluation ThinPrep slides compared with historical cohort of conventional Pap slides for specimen adequacy and yield of abnormal diagnoses Histologic verification of most ThinPrep HSIL. No verification of test-negatives | ThinPrep vs. conventional smear ThinPrep Direct to vial | Vermont 1997 12 practice sites that chose to offer ThinPrep | Uncertain sample collection. Spectrum not described | Specimen adequacy and yield of abnormal diagnoses Thresholds for ThinPrep and conventional smear of ASCUS/AGUS, LSIL, SIL NOS, HSIL | No reference standard; compared only to historical cohort of conventional smear samples. Prevalence of disease unknown Histologic verification of most ThinPrep HSIL ThinPrep resulted in more abnormal diagnoses (ASCUS+) than historical conventional smear, and less unsatisfactory or limited smears PPV of ThinPrep for HSIL=93.2% Historical Positive Predictive Value of conventional smear for HSIL=78.8% | Quality Score=1.5 Ref. Std: 0 Blind: 0 Verification: 0 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: .5
Sherman et al., 1998^ 108 ^ | Diagnostic test evaluation, conventional Pap vs. ThinPrep Data from ThinPrep clinical trial All abnormals, and random 5% of test-negatives verified by independent cytologists and pathologists No histologic verification of test-positives. Diagnoses compared with HPV results | Conventional Pap vs. ThinPrep. Split sample collected with broom device | US 1996 6 sites; 3 community clinics and 3 hospitals | 1954 slides: 895 discrepant results, 759 concordant positives, and 300 random negatives from clinical trial | Blind interpretation Sensitivity of ThinPrep and conventional smear as compared to most abnormal reference cytology diagnosis PPV estimated by comparison with HPV type | Unable to get estimate of specificity because no test positives verified with histology Se ThinPrep (HSIL)=88.6% Se conventional smear (HSIL)=81.2% No difference in HPV detection in smears called abnormal between conventional smear and ThinPrep More cancer-associated HPV types seen in ThinPrep+ patients. Very few HPV+ in 300 random test-negatives | Quality Score=4.5 Ref. Std: 0 Blind: 2 Verification: 1 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: .5
Hutchinson et al, 1999^ 109 ^ | Diagnostic test evaluation Verification of test negatives in random sample of 150 women Pap, ThinPrep^®^ vs. colposcopy /biopsy (Other methods tested: Papnet^®^, cervioscopy but results not reported in this paper) | Conventional pap smear using split samples & ThinPrep^®^ Collection method: Cervex Brush^®^ (Unimar) | Guanacaste Costa Rica, time period not given | 8636 in final analysis, non-virgin, non- pregnant women Aged (not given) | ThinPrep^®^ results: ASCUS, LGSIL, HSIL, carcinoma GS: colposcopy-directed biopsy: reported as equivocal, LSIL, HSIL, cancer | Prevalence (LGSIL on colposcopy) =186/8636=2.2% Se (ASCUS ThinPrep^®^, LGSIL colp)=31.8% Sp ASCUS ThinPrep^®^, LGSIL colp)=93.2% Se (LGSIL ThinPrep^®^, LGSIL colp)=78.7% Sp (LGSIL ThinPrep^®^, LGSIL colp)=100% Prevalence (HGSIL on colposcopy) =126/8636=1.5% Se (LGSIL ThinPrep^®^, HGSIL colp)=71.9% Sp (LGSIL ThinPrep^®^, HGSIL colp)=100% Se (HGSIL ThinPrep^®^, HGSIL colp)=89.4% Sp (HGSIL ThinPrep^®^, HGSIL colp)=99.9% Limits: uncertain time between Pap and colposcopy | Quality Score=6 Ref. Std:1 Blind:0 Verification:1 Consecutive:2 Spectrum:1 BR>Publication:1 Industry:1
Weintraub and Morabia, 2000^ 49 ^ | In community-based screening, diagnostic test evaluation of ThinPrep^®^ compared to results obtained with standard Pap Reference standard: histology (among Pap +) | Results obtained by conventional Pap versus ThinPrep^®^ ThinPrep^®^ collection method: Cervex Brush^®^ (Unimar) | Europe ThinPrep^®^ samples obtained from 11/1/96-12/31/97; conventional 1/1/95-12/31/97 | 39,864 ThinPrep^®^ slides and 130,381 conventional Paps Reference standard results available for 509 | Pap results: Bethesda Histologic diagnosis: negative, inconclusive, LSIL, HSIL | Prevalence: LSIL=117/509=23.0% HSIL=196/509=38.5% Ca=6/509=1.2% No gold standard verification of ThinPrep^®^ negatives | Quality Score=8 Ref. Std:1 Blind:2 Verification:0 Consecutive:2 Spectrum:1 Publication:1 Industry:1

*Format for display of results of conventional Pap test: Prevalence (GS threshold)=disease/total=%; Sensitivity (Pap threshold/GS threshold)=true positive/disease=%; Specificity (Pap threshold/GS threshold)=true negatives/non-diseased=%

Evidence Table 3A. Performance of HPV Testing for ScreeningAppendix CEvidence Tables

Source: Author, Year | Study Design & Characteristics | Interventions | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations* | Quality Considerations
Cuzick et al., 1999^ 21 ^ | Diagnostic test evaluation among older population undergoing routine screening for HPV and assessment of outcome by colposcopy Pap negatives not verified, HPV negatives verified except for Hybrid Capture where a sample of negative controls were evaluated | HPV testing of Pap results using consensus PCR/ SHARP detection for high risk subtypes, and Hybrid Capture I and Hybrid Capture II | 40 gynecologic practices in UK Time period not specified | 2,988 women 34 and older undergoing routine care | Cytology read as inadequate, negative, borderline, mild, moderate, severe, glandular atypia High risk HPV subtypes (16, 18, 31, 33, 35, 51, 522, 56, 58), other and negative Histology: Inadequate, Negative/no biopsy, borderline/CIN 1, CIN 2, CIN 3, Adeno in situ | Prevalence: Negative/no biopsy=2855/2988 =95.6% HPV/borderline=57/2988 =1.9% CIN 1=27/2988=0.9% CIN 2=8/2988=0.3% CIN 3=33/2988=1.1% Adeno in situ=1/2988=0.03% HC II: Se (High risk HPV, LGSIL+)=61.0% Sp (High risk HPV, LGSIL+)=95.1 % Se (High risk HPV, HGSIL+)=95.2 % Sp (High risk HPV, HGSIL+)=94.3 % | Quality Score=11 Ref. Std:2 Blind:2 Verification:2 Consecutive:2 Spectrum:1 Publication:1 Industry:1
Petry et al., 1999^ 61 ^ | Diagnostic test evaluation (HPV) among HIV+ population and assessment of outcome by colposcopy; study also contains an incidence arm | HPV testing of Pap results using Hybrid Capture I | Germany 1990-1998 | 138 HIV-infected women visiting gynecologic clinic for any reason | cytology: any atypia, >/= CIN I, >/= CIN II HPV: high risk types (16, 18, 31, 33, 35, 45, 51, 52, 56) vs. not histology: CIN II, CIN III or invasive cancer | Prevalence: CIN I=20/138=14.5% CIN II=5/138=3.6% CIN III=9/138=6.5% invasive ca=3/138=2.2% Se (High risk HPV, CIN II +)= 94.1% Sp (High risk HPV, CIN II +)= 70.3% | Quality Score=9 Ref. Std: 2 Blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Schiffman et al., 2000^ 65 ^ | Diagnostic test evaluation (HPV) among high incidence population and assessment of outcome by combining screening results with biopsy results Pap/ cervicography negatives verified by colposcopy in a 2% random sample | HPV testing of Pap results using Hybrid Capture Tube (HCT) and Hybrid Capture II (on a smaller subset of samples) | Guanacaste Province, Costa Rica 1993-1994 | 8554 women randomly selected in a door-to door survey | cytology: Bethesda system HPV: : high risk types (16, 18, 31, 33, 35, 45, 51, 52, 56 and 58) vs. not histology :negative, equivocal, low-grade lesion, high-grade lesion, cancer | Prevalence: Negative=7564/8554=88.4% Equivocal=661/8554=7.7% LG lesion=189/8554=2.2% HG lesion=128/8554=1.5% Cancer=12/8554=0.14% Se (High risk HPV by HCT, HG+)= 74.1% Sp (High risk HPV by HCT, HG+)= 93.4% Se (High risk HPV by HC II, HG+)= 88.4% Sp (High risk HPV by HC II, HG+)= 89.0% (more screening performance results available for different cutpoints of HPV positivity) | Quality Score=9 Ref. Std: 2 Blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Womack et al, 2000a^ 63 ^ | Diagnostic test evaluation (HPV) among population at high risk for HIV | HPV testing using Hybrid Capture II assay, probe B (13 high risk subtypes) and assessment of outcome by biopsy/ colposcopy | Chitungwiza and the greater Harare area, Zimbabwe c. 1999 | 466 women aged 25 to 55 attending primary care clinics | HPV: high risk subtypes (16, 18, 31, 33, 35, 45, 51, 52, 56 and 58) vs. not Biopsy/colposcopy: Normal, low-grade lesion, high-grade lesion, cancer | Prevalence: Negative=350/466=75.1% LGSIL=60/466=12.9% HGSIL=56/466=12% for HIV+ women: Se (High risk HPV, LGSIL+)= 85.9% Sp (High risk HPV, LGSIL+)= 47.0% Se (High risk HPV, HGSIL)= 90.7% Sp (High risk HPV, HGSIL)= 41.3% for HIV- women: Se (High risk HPV, LGSIL+)=45.2% Sp (High risk HPV, LGSIL+)=75.3% Se (High risk HPV, HGSIL)= 61.5% Sp (High risk HPV, HGSIL)= 74.5% | Quality Score=9 Ref. Std: 2 Blind: 2 Verification: 2 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1
Womack et al., 2000b^ 62 ^ | Diagnostic test evaluation for primary screening | HPV testing using Hybrid Capture II assay, probe B (13 high risk subtypes) and assessment of outcome by biopsy/ colposcopy for all participants Testing of HPV viral load using relative light unit ratios Colposcopists blinded to results of HPV tests and visual inspection | Chitungwiza and the greater Harare area, Zimbabwe, Oct 1996-1997 | 2140 women aged 25 to 55 attending primary care clinics | Primary outcome: High grade lesions or cancer (proved by biopsy and/or colposcopic impression) Low grade lesions (proved by biopsy and/or colposcopic impression) Secondary outcome: Light unit ratios of HPV positive specimens | Prevalence: LGSIL=561/2140=26.2% HGSIL=251/2140=10.1% Se (High risk HPV, LGSIL+) =64.0% Sp (High risk HPV, LGSIL+) =64.9% Se (High risk HPV, HGSIL+) = 80.9% Sp (High risk HPV, HGSIL+) = 61.6% | Quality Score=9 Ref. Std: 2 Blind: 2 Verification: 2 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1
Wright et al., 2000^ 64 ^ | Diagnostic test evaluation (HPV) among population also screened using Pap, direct visual inspection, cervicography and assessment of outcome by biopsy/ colposcopy Abnormals on any test referred for verification | HPV testing using Hybrid Capture II assay in both patient collected and physician collected specimens | Environs of CapeTown, South Africa 1998-1999 | 1365 previously unscreened black women aged 35 and older attending outpatient clinics | cytology: Bethesda system HPV: high risk subtypes (16, 18, 31, 33, 35, 45, 51, 52, 56 and 58) vs. not Colposcopy: biopsy-confirmed HGSIL, or cancer | Prevalence: LGSIL=40/1365=2.9% HGSIL=47/1365=3.4% Ca=9/1365=0.7% for clinican-collected specimens: Se (High risk HPV, LGSIL+)=81.3% Sp (High risk HPV, LGSIL+)=84.5% for self-collected specimens: Se (High risk HPV, LGSIL+)= 61.5% Sp (High risk HPV, LGSIL+)= 74.5% for clinican-collected specimens: Se (High risk HPV, HGSIL+)=81.3% Sp (High risk HPV, HGSIL+)=84.5% for self-collected specimens: Se (High risk HPV, HGSIL+)= 66.1% Sp (High risk HPV, HGSIL+)= 82.9% | Quality Score=9 Ref. Std: 2 Blind: 2 Verification: 2 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1

Evidence Table 3B. Performance of HPV Testing for TriageAppendix CEvidence Tables

Source: Author, Year | Study Design & Characteristics | Interventions | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations* | Quality Considerations
Herrington et al., 1995^ 69 ^ | Diagnostic test evaluation among abnormal Paps; screening for HPV compared with colpsocopy/ Histology Pap negatives not verified | HPV testing of abnormal Paps using two tests: Consensus PCR and in situ hybridization | Time period not specified | 167 patients with abnormal Paps referred for colposcopy | Primary outcome: Wart virus changes, CIN I, II, III or invasive carcinoma | Prevalence: WVC or CIN I =88/167=52.6% CIN II, III or ca =40/167=24.0% Se (PCR, >CIN II)=87.5% Sp (PCR, >CIN II)=62.2% | Quality Score=5 Ref. Std.:2 Blind: 0 Verification: 0 Consecutive:0 Spectrum:1 Publication:1 Industry:1
Sun et al., 1995^ 73 ^ | Diagnostic test evaluation among women referred to a colposcopy clinic | HPV testing of abnormal Paps using Hybrid Capture I and consensus PCR | New York, NY or Montreal, Quebec 1992-1993 | 520 women referred to colposcopy clinic | Primary outcome: Low grade CIN High grade CIN or cancer Secondary outcome: Amount of HPV DNA by relative light unit reading | Prevalence: LG CIN = 161/520=31% HG CIN or ca= 105/520=20.2% Se (HC, >CIN I)=58.3% Sp (HC, >CIN I)=69.3% Se (HC, >CIN II)=66.7% Sp (HC, >CIN II)=60.7% Se (PCR, >CIN I)=84.6% Sp (PCR, >CIN I)=48.0% Se (PCR, >CIN II)=82.9% Sp (PCR, >CIN II)=34.9% | Quality Score=4.5 Ref. Std.:2 Blind: 0 Verification: 0 Consecutive:0 Spectrum:1 Publication:1 Industry:0.5
Bollen et al., 1997^ 66 ^ | Diagnostic test evaluation among abnormal Paps; screening for HPV and type compared with colpsocopy/histology Pap negatives not verified, HPV negatives verified | HPV testing of abnormal Paps using two tests: CPI/IIG primer pair and MY09/11 polymerase chain reaction using SHARP signal system and probe sets A & B Colposcopy and histology | Amsterdam 1994-1995 | 190 consecutive mildly/moderately abnormal Paps referred for colposcopy | Blinded to HPV status while performing colposcopy HPV presence and type by CPI/IIG PCR, HPV presence by SHARP probe Histologic diagnosis: no dysplasia or LGSIL vs. HGSIL | Prevalence: LGSIL or none=134/190=70.5% HGSIL or none=56/190=29.5% Se (CPI/IIG, HSIL)=96% Sp (CPI/IIG)=33% Se (HPV subtypes 16,18,31,33,45/HGSIL)=68% Sp (HPV subtypes type16,18,31,33,45/HGSIL)=70% Se (SHARP Probe B, HSIL)=95% Sp (SHARP Probe B, HSIL)=40% Using both HPV tests: Se (SHARP Probe B +CPI/IIG, HSIL)=98% Sp (SHARP Probe B+CPI/IIG, HSIL)=28% | Quality Score=11 Ref. Std.:2 Blind:2 Verification:2 Consecutive:2 Spectrum:1 Publication:1 Industry:1
Sigurdsson et al, 1997^ 67 ^ | Descriptive study of HPV expression in 358 abnormal smears referred for colposcopy. Pap negatives not verified | 1) Cytologic and histopathologic findings, 2) Presence and amount of HPV by hybrid capture and PCR, 3) Presence of HPV in swabs and biopsies, 4) Distribution of HPV type by cyto- and histopathological findings | Population based screening program, Iceland 1994 | 358 women diagnosed with and not treated earlier for abnormal smears referred for colposcopy | Cytology: Bethesda system Colposcope-directed biopsies and histology: negative, koilocytotic changes, CIN I, II, III, cancer HPV testing: Hybrid: high risk + intermediate risk=high risk (types 16, 18, 31, 33, 35, 45, 51, 52, and 56), vs. low risk (6, 11, 42, 43, 44) PCR: high risk (16, 18, 31, 33 and 35) vs. low (6, 11) or unclassified (other than these.) | | Quality Score=8 Ref. Std.: 1 Blind: 2 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Adam et al., June 1998^ 71 ^ | Diagnostic test evaluation among population w/2 minimally abnormal Paps or 1 highly abnormal; screening for HPV and type compared with colpsocopy/histology Pap negatives not verified, HPV negatives verified | HPV testing of abnormal Paps using PCR primer pair MY09/11 to identify high risk types 16, 18, 31, 33 and 35 | Indigent population in Harris County, TX Time period not specified | 1007 women with abnormal Paps referred for colposcopy | Pap diagnosis classified by Bethesda system HPV defined as negative consensus, 16, 18, 31&33&35, any high risk subtype, all multiple high risk subtypes, and unidentified type Histology: No CIN/ CIN 1/HPV, CIN 2, CIN 3/CIS, invasive carcinoma | Prevalence: No CIN=269/1007=27% CIN 1 w/HPV changes=477/1007=47% CIN II 124/1007=13% CIN III/CIS=12% Invasive carcinoma=4/1007=0.4% Se (High risk HPV, CIN II/III)=59% Sp (High risk HPV, CIN II/III)=59% Se (High risk HPV, CIN I +)=51% Sp (High risk HPV, CIN I +)=67% | Quality Score=9 Ref. Std.: 2 Blind: 2 Verification: 2 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1
Manos et al., May 1999^ 68 ^ | Diagnostic test evaluation among population with ASCUS results from ThinPrep® Pap, screening for HPV and assessment of outcome by colposcopy Pap negatives not verified, HPV negatives verified | HPV testing of ASCUS ThinPrep® Pap results using Hybrid Capture II assay | Northern California HMO population 1995-1996 | 973 women undergoing routine screening with ASCUS Pap results and histologic diagnosis | ThinPrep® Pap diagnosis classified as ASCUS HPV + for high risk subtypes 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58 Histology: normal, LSIL, HSIL, Cancer | Prevalence: Normal=783/973=80.4% LSIL=125/973=12.8% HSIL=64/973=6.7% Cancer=1/973=0.1% Se (High risk HPV, LGSIL+)=76.3% Sp (High risk HPV, LGSIL+)=69.5% Se (High risk HPV, HGSIL+)=89.2% Sp (High risk HPV, HGSIL+)=64.1% | Quality Score=11 Ref. Std.: 2 Blind: 2 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Hillemanns et al., 1999^ 72 ^ | Diagnostic test evaluation (HPV) for detection of high grade lesions | Testing of self collected specimens and physician collected specimens for HPV using Hybrid Capture II | Munich, Germany Time period not specified | 247 patients attending a colposcopy clinic | Primary outcome: CIN I, II, II, invasive cancer | Prevalence: CIN I =18/247=7.3% >CIN II=40/247=16.2% Physician collected samples: se (HPV, >CIN II+)=92.5% sp (HPV, >CIN II+)=72.5% Patient collected samples: se (HPV, >CIN II+)=92.5% sp (HPV, >CIN II+)=61.8% | Quality Score=7 Ref. Std.: 2 Blind: 0 Verification: 2 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1