# Appendix B. Methods

## Uspstf Cervical Cancer Screening

Article Screen & Abstract

### Key Question 1A: Who should be screened for cervical cancer and how often?

Specifically, what are the outcomes (benefits, harms, and costs) associated with screening among women age 65 and older?

Key Question 1A: Who should be screened for cervical cancer and how often?

Initials of Reviewer __ __ __ | Date __ / __ / __ (mm,dd,yy) | Unique Article Identifier __ __ __ __

#### Screen

Is this an original research article? | [image] Yes | [image] No
Does the study address screening/outcomes of screening for squamous cell carcinoma of the cervix? | [image] Yes | [image] No
Is the age distribution of the study population specified? | [image] Yes | [image] No
Are women > 50 years old included? | [image] Yes | [image] No
Is stratified data about outcomes/risk/etc. provided by age? | [image] Yes | [image] No
Is the denominator provided from which the cases arose? | [image] Yes | [image] No*
*If not, are rates provided that indicate the denominator is known? | [image] Yes | [image] No

ALL ABOVE MUST BE "YES" TO INCLUDE FOR KQ3 | [image] Include | [image] Reject

Other Screening Questions
Does the article include histologically verified measures of Pap test or HPV test diagnostic characteristics? | [image] Yes | [image] No
Does the article report findings for women who have had a hysterectomy? | [image] Yes | [image] No
Does the article report costs of screening based on actual cost of care in the US? | [image] Yes | [image] No
Does the article report harms of screening/testing? | [image] Yes | [image] No

## USPSTF CERVICAL CANCER SCREENING

Article Screen & Abstract

### Key Question 1B: Who should be screened for cervical cancer and how often?

What are the outcomes (benefits, harms, and costs) associated with screening among women who have had a hysterectomy?

Key Question 1B: Who should be screened for cervical cancer and how often?

Initials of Reviewer __ __ __ | Date __ / __ / __ (mm,dd,yy) | Unique Article Identifier __ __ __ __

#### SCREEN

Is this an original research article? | [image] Yes | [image] No
Does the study address screening/outcomes of screening for squamous cell carcinoma of the cervix? | [image] Yes | [image] No
Are outcomes of screening compared for women with and without a hysterectomy? | [image] Yes | [image] No

ALL ABOVE MUST BE "YES" TO INCLUDE FOR KQ3 | [image] Include | [image] Reject

Other Screening Questions
Does the article include histologicaly verified measures of Pap test or HPV test diagnostic characteristics? | [image] Yes | [image] No
Does the article include stratification by age, with women age 50 or older included? | [image] Yes | [image] No
Does the article report costs of screening based on actual cost of care in the US? | [image] Yes | [image] No
Does the article report harms of screening/testing? | [image] Yes | [image] No

## USPSTF CERVICAL CANCER SCREENING

Article Screen & Abstract

### Key Question 2: Do new methods for preparing/evaluating cervical cytology improve diagnostic yield?

Key Question 2: Do new methods for preparing/evaluating cervical cytology improve diagnostic yield?

Initials of Reviewer __ __ __ | Date __ / __ / __ (mm,dd,yy) | Unique Article Identifier __ __ __ __

#### SCREEN

The new method(s) under evaluation: _______________________

Is this an original research article? | [image] Yes | [image] No
Was Pap testing done as a screening test? | [image] Yes | [image] No
Does the study include at least 50 subjects/specimens with Pap results and new method testing? | [image] Yes | [image] No
Was the new method used for primary screening or as an adjunct to primary screening? | [image] Yes | [image] No
Were Pap and the new method compared with a reference standard (histology/colposcopy)? | [image] Yes | [image] No
Were the Pap, new test, and reference standard obtained within a three month window? | [image] Yes | [image] No
Can all cells of a 2x2 table be completed? | [image] Yes | [image] No

ALL ABOVE MUST BE "YES" TO INCLUDE FOR KQ2 | [image] Include | [image] Reject

Other Screening Questions
Does the article include stratification by age, with women age 50 or older included? | [image] Yes | [image] No
Does the article report findings for women who have had a hysterectomy? | [image] Yes | [image] No
Does the article report costs of screening based on actual cost of care in the US? | [image] Yes | [image] No
Does the article report harms of screening/testing? | [image] Yes | [image] No

## USPSTF CERVICAL CANCER SCREENING

Article Screen & Abstract

### Key Question 3: What is the role of HPV testing in cervical cancer screening strategies?

Key Question 3: What is the role of HPV testing in cervical cancer screening strategies?

Initials of Reviewer __ __ __ | Date __ / __ / __ (mm,dd,yy) | Unique Article Identifier __ __ __ __

#### SCREEN

Is this an original research article? | [image] Yes | [image] No
Was Pap testing done as a screening test? | [image] Yes | [image] No
Does the study include at least 50 subjects/specimens with Pap results and HPV testing? | [image] Yes | [image] No
Was HPV testing used for primary screening or as an adjunct to primary screening? | [image] Yes | [image] No
Were Pap and HPV testing compared with a reference standard (histology/colposcopy)? | [image] Yes | [image] No
Were the Pap, HPV test, and reference standard obtained within a three month window? | [image] Yes Elapsed time: ___ | [image] No [image] DK
Can all cells of a 2x2 table be completed? | [image] Yes | [image] No

ALL ABOVE MUST BE "YES" TO INCLUDE FOR KQ3 | [image] Include | [image] Reject

Other Screening Questions
Does the article include stratification by age, with women age 50 or older included? | [image] Yes | [image] No
Does the article report findings for women who have had a hysterectomy? | [image] Yes | [image] No
Does the article report harms of screening/testing? | [image] Yes | [image] No