# Appendix A. Acknowledgments

This study was supported by Contract 290-97-0011 from the Agency for Healthcare Research and Quality (Task No. 3 to support the US Preventive Services Task Force). We acknowledge the ongoing guidance of David Atkins, M.D., M.P.H., Director of the Preventive Services Program at AHRQ, and the continuing support of Jacqueline Besteman, J.D., M.A., the AHRQ Task Order Officer for this project. The investigators deeply appreciate the considerable support and contributions of faculty and staff from the University of North Carolina at Chapel Hill - Russ Harris, M.D., M.P.H., Michael Pignone, M.D., M.P.H., Lynn Whitener, Dr.P.H., M.S.L.S., Barbara Starrett, M.H.A., Catherine Mills Burchell, M.A., and Scott Pohlman, M.S. We would like to express our special thanks to those who helped in so many practical ways to prepare the final document - Cheryl Roman, B.A., Christine Shia, M.A., and Melissa McPheeters, M.P.H.

We are equally grateful to Kathleen Lohr, Ph.D., Linda Lux, M.P.H., Anjolie Idicula Laubach, B.A., and Sonya Sutton, B.S.P.H., from RTI International for their continued guidance and assistance with the project and to Sheila White and Loraine Monroe for superior secretarial support. In addition, we would like to extend our thanks to the following expert peer reviewers, who provided input on an earlier version of this report: Michael L. LeFevre, M.D., M.S.P.H., of the University of Missouri School of Medicine, Columbia, MO; Jean-Marie Moutquin, M.D., M.Sc., F.R.S.C.(C).of the Canadian Task Force on Preventive Care, Sherbrooke, Quebec; Evan Myers, M.D., M.P.H., of Duke University Medical Center, Durham, N.C.; Kenneth Noller, M.D., of the American College of Obstetricians and Gynecologists, Washington, D.C.; and Electra Paskett, Ph.D., of the Wake Forest University Baptist Medical Center, Winston-Salem, N.C.