# References

1 US Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Primary Care Interventions to Support Breastfeeding: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;316(16):1688–93. PMID: 27784102. 10.1001/jama.2016.14697 27784102
2 Patnode CD, Henninger ML, Senger CA, . Primary Care Interventions to Support Breastfeeding: Updated Systematic Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality; 2016. PMID: 2785440327854403.
3 Patnode CD, Henninger ML, Senger CA, . Primary Care Interventions to Support Breastfeeding: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2016;316(16):1694–705. PMID: 27784101. 10.1001/jama.2016.8882 27784101
4 Rasmussen KM, Felice JP, O’Sullivan EJ, . The Meaning of “Breastfeeding” Is Changing and So Must Our Language About It. Breastfeed Med. 2017;12(9):510–4. PMID: 28686471. 10.1089/bfm.2017.0073 28686471
5 Centers for Disease Control and Prevention and National Immunization Survey. CDC National Immunization Surveys (NIS) 2020 and 2021: Rates of Any and Exclusive Breastfeeding by Socio–demographics among Children Born in 2021. Atlanta, GA: Centers for Disease Control and Prevention; 2022.
6 Chiang KV, Li R, Anstey EH, . Racial and Ethnic Disparities in Breastfeeding Initiation horizontal line United States, 2019. MMWR Morb Mortal Wkly Rep. 2021;70(21):769–74. PMID: 34043611. 10.15585/mmwr.mm7021a1 34043611
7 Beauregard JL, Hamner HC, Chen J, . Racial Disparities in Breastfeeding Initiation and Duration Among U.S. Infants Born in 2015. MMWR Morb Mortal Wkly Rep. 2019;68(34):745–8. PMID: 31465319. 10.15585/mmwr.mm6834a3 31465319
8 Anstey EH, Chen J, Elam-Evans LD, . Racial and Geographic Differences in Breastfeeding - United States, 2011-2015. MMWR Morb Mortal Wkly Rep. 2017;66(27):723–7. PMID: 28704352. 10.15585/mmwr.mm6627a3 28704352
9 Hamner HC, Beauregard JL, Li R, . Meeting breastfeeding intentions differ by race/ethnicity, Infant and Toddler Feeding Practices Study-2. Matern Child Nutr. 2021;17(2):e13093. PMID: 33006242. 10.1111/mcn.13093 33006242
10 Centers for Disease Control and Prevention. Breastfeeding Among U.S. Children Born 2011–2018, CDC National Immunization Survey. 2020.
11 Centers for Disease Control and Prevention NIS. Rates of Any and Exclusive Breastfeeding by Sociodemographics among Children Born in 2018. 2020. Accessed November 2, 2021. Available from: https://www.cdc.gov/breastfeeding/data/nis_data/rates-any-exclusive-bf-socio-dem-2018.html
12 FAO I, UNICEF, WFP and WHO. The State of Food Security and Nutrition in the World 2019. Urbanization, agrifood systems transformation and healthy diets across the rural-urban continuum. Rome. 2023. Available from: 10.4060/cc3017en
13 Global Breastfeeding Collective, UNICEF and WHO. Global Breastfeedign Scorecard 2023: Rates of breastfeeding increase around the world through improved protection and support. WHO & UNICEF; 2023. Available from: https://www.unicef.org/documents/global-breastfeeding-scorecard-2023
14 UNICEF. Breastfeeding: A Mother’s Gift, for Every Child. New York, NY. 2018. Available from: https://www.unicef.org/media/48046/file/UNICEF_Breastfeeding_A_Mothers_Gift_for_Every_Child.pdf
15 American Academy of Pediatrics. Breastfeeding and the use of human milk. Pediatrics. 2012;129(3):e827–41. PMID: 22371471. 10.1542/peds.2011-3552 22371471
16 American Academy of Family Physicians. Breastfeeding, Family Physicians Supporting (Position Paper). 2015. Available from: https://www.aafp.org/about/policies/all/breastfeeding-position-paper.html
17 American Academy of Family Physicians. Breastfeeding (Policy Statement). 2017. Available from: https://www.aafp.org/about/policies/all/breastfeeding-policy-statement.html
18 American College of Obstetricians and Gynecologists. ACOG Committee Opinion No. 756: Optimizing Support for Breastfeeding as Part of Obstetric Practice. Obstet Gynecol. 2018;132(4):e187–e96. PMID: 30247365. 10.1097/aog.0000000000002890 30247365
19 U.S. Department of Agriculture USDoHaHS. Dietary Guidelines for Americans, 2020-2025. 9th Edition. 2020. Available from: http://www.dietaryguidelines.gov/
20 World Health Organization. Indicators for assessing infant and young child feeding practices: definitions and measurement methods. Geneva: World Health Organization; 2021. https://www.who.int/publications/i/item/9789240018389.
21 World Health Organization. Health Topics: Breastfeeding. Available from: https://www.who.int/health-topics/breastfeeding#tab=tab_1
22 Meek JY, Noble L and Section on B. Policy Statement: Breastfeeding and the Use of Human Milk. Pediatrics. 2022;150(1):e2022057988. Available from: https://publications.aap.org/pediatrics/article/150/1/e2022057988/188347/Policy-Statement-Breastfeeding-and-the-Use-of. 10.1542/peds.2022-057988 35921640
23 Labbok M and Krasovec K. Toward consistency in breastfeeding definitions. Stud Fam Plann. 1990;21(4):226–30. PMID: 2219227.2219227
24 World Health Organization. Global Strategy for Infant and Young Child Feeding. In: (UNICEF) WHOUNCsF, editor. Geneva. 2003. Available from: https://www.who.int/publications/i/item/9241562218
25 U.S. Department of Health and Human Services. Increase the proportion of infants who are breastfed exclusively through age 6 months — MICH-15. 2021. Available from: https://health.gov/healthypeople/objectives-and-data/browse-objectives/infants/increase-proportion-infants-who-are-breastfed-exclusively-through-age-6-months-mich-15
26 U.S. Department of Health and Human Services. Increase the proportion of infants who are breastfed at 1 year — MICH-16. 2021. Available from: https://health.gov/healthypeople/objectives-and-data/browse-objectives/infants/increase-proportion-infants-who-are-breastfed-1-year-mich-16
27 Ip S, Chung M, Raman G, . Breastfeeding and maternal and infant health outcomes in developed countries. Evid Rep Technol Assess (Full Rep). 2007(153):1–186. PMID: 17764214.17764214
28 Patnode CD, Henrikson NB, Webber EM, . Breastfeeding and Health Outcomes for Infants and Children. Systematic Review. (Prepared by the Kaiser Permanente Evidence-based Practice Center under Contract No. 75Q80120D00004.) AHRQ Publication No. 25-EHC014. Rockville, MD: Agency for Healthcare Research and Quality. March 2025. 10.23970/AHRQEPCSRBREASTFEEDING
29 Xue M, Dehaas E, Chaudhary N, . Breastfeeding and risk of childhood asthma: a systematic review and meta-analysis. ERJ Open Res. 2021;7(4). PMID: 34912884. 10.1183/23120541.00504-2021 34912884
30 Güngör D, Nadaud P, LaPergola CC, . Infant milk-feeding practices and food allergies, allergic rhinitis, atopic dermatitis, and asthma throughout the life span: a systematic review. Am J Clin Nutr. 2019;109(Suppl_7):772s–99s. PMID: 30982870. 10.1093/ajcn/nqy283 30982870
31 Zheng M, D’Souza NJ, Atkins L, . Breastfeeding and the Longitudinal Changes of Body Mass Index in Childhood and Adulthood: A Systematic Review. Adv Nutr (Bethesda). 2024;15(1):100152. PMID: 37977327. 10.1016/j.advnut.2023.100152 37977327
32 Horta BL, Rollins N, Dias MS, . Systematic review and meta-analysis of breastfeeding and later overweight or obesity expands on previous study for World Health Organization. Acta Paediatr. 2023;112(1):34–41. PMID: 35727183. 10.1111/apa.16460 35727183
33 Dewey K, Bazzano L, Davis T, . The Duration, Frequency, and Volume of Exclusive Human Milk and/or Infant Formula Consumption and Overweight and Obesity: A Systematic Review. USDA Nutrition Evidence Systematic Review. USDA Nutrition Evidence Systematic Reviews. Alexandria (VA): United States Department of Agriculture; 2020. PMID. 10.52570/NESR.DGAC2020.SR0301
34 Su Q, Sun X, Zhu L, . Breastfeeding and the risk of childhood cancer: a systematic review and dose-response meta-analysis. BMC Med. 2021;19(1):90. PMID: 33845843. 10.1186/s12916-021-01950-5 33845843
35 Gong QQ, Quan DD, Guo C, . Association between maternal breastfeeding and risk of systemic neoplasms of offspring. Ital J Pediatr. 2022;48(1):98. PMID: 35710389. 10.1186/s13052-022-01292-9 35710389
36 Duijts L, Ramadhani MK and Moll HA. Breastfeeding protects against infectious diseases during infancy in industrialized countries. A systematic review. Matern Child Nutr. 2009;5(3):199–210. PMID: 19531047. 10.1111/j.1740-8709.2008.00176.x 19531047
37 Hoang MP, Samuthpongtorn J, Seresirikachorn K, . Prolonged breastfeeding and protective effects against the development of allergic rhinitis: a systematic review and meta-analysis. Rhinology. 2022;60(2):82–91. PMID: 34783797. 10.4193/Rhin21.274 34783797
38 Boronat-Catala M, Montiel-Company JM, Bellot-Arcis C, . Association between duration of breastfeeding and malocclusions in primary and mixed dentition: a systematic review and meta-analysis. Sci Rep. 2017;7(1):5048. PMID: 28698555. 10.1038/s41598-017-05393-y 28698555
39 Teshome A and Girma B. The Impact of Exclusive Breastfeeding on Malocclusion: a Systematic Review. SN Comprehensive Clinical Medicine. 2021;3(1):95–103. PMID. 10.1007/s42399-020-00672-8
40 Agrawal M, Sabino J, Frias-Gomes C, . Early life exposures and the risk of inflammatory bowel disease: Systematic review and meta-analyses. EClinicalMedicine. 2021;36:100884. PMID: 34308303. 10.1016/j.eclinm.2021.100884 34308303
41 Gungor D, Nadaud P, LaPergola CC, . Infant milk-feeding practices and diabetes outcomes in offspring: a systematic review. Am J Clin Nutr. 2019;109(Suppl_7):817S–37S. PMID: 30982877. 10.1093/ajcn/nqy311 30982877
42 Cardwell CR, Stene LC, Ludvigsson J, . Breast-feeding and childhood-onset type 1 diabetes: a pooled analysis of individual participant data from 43 observational studies. Diabetes Care. 2012;35(11):2215–25. PMID. 10.2337/dc12-0438 22837371
43 Horta BL, Loret de Mola C and Victora CG. Long-term consequences of breastfeeding on cholesterol, obesity, systolic blood pressure and type 2 diabetes: a systematic review and meta-analysis. Acta Paediatr. 2015;104(467):30–7. PMID: 26192560. 10.1111/apa.13133 26192560
44 Thompson JMD, Tanabe K, Moon RY, . Duration of Breastfeeding and Risk of SIDS: An Individual Participant Data Meta-analysis. Pediatrics. 2017;140(5). PMID: 29084835. 10.1542/peds.2017-1324 29084835
45 Hauck FR, Thompson JM, Tanabe KO, . Breastfeeding and reduced risk of sudden infant death syndrome: a meta-analysis. Pediatrics. 2011;128(1):103–10. PMID: 21669892. 10.1542/peds.2010-3000 21669892
46 Ware JL, Li R, Chen A, . Associations Between Breastfeeding and Post-perinatal Infant Deaths in the U.S. Am J Prev Med. 2023;65(5):763–74. PMID: 37220859. 10.1016/j.amepre.2023.05.015 37220859
47 Walfisch A, Sermer C, Cressman A, . Breast milk and cognitive development--the role of confounders: a systematic review. BMJ Open. 2013;3(8):e003259. PMID: 23975102. 10.1136/bmjopen-2013-003259 23975102
48 Lin B, Dai R, Lu L, . Breastfeeding and Atopic Dermatitis Risk: A Systematic Review and Meta-Analysis of Prospective Cohort Studies. Dermatology. 2020;236(4):345–60. PMID: 31694017. 10.1159/000503781 31694017
49 Güngör D, Nadaud P, Dreibelbis C, . Infant milk-feeding practices and diagnosed celiac disease and inflammatory bowel disease in offspring: a systematic review. Am J Clin Nutr. 2019;109(Suppl_7):838s–51s. PMID: 30982875. 10.1093/ajcn/nqy371 30982875
50 Szajewska H, Shamir R, Strozyk A, . Systematic review: early feeding practices and the risk of coeliac disease. A 2022 update and revision. Aliment Pharmacol Ther. 2023;57(1):8–22. PMID: 36411726. 10.1111/apt.17290 36411726
51 Lodge CJ, Tan DJ, Lau MX, . Breastfeeding and asthma and allergies: a systematic review and meta-analysis. Acta Paediatr. 2015;104(467):38–53. PMID: 26192405. 10.1111/apa.13132 26192405
52 Chowdhury R, Sinha B, Sankar MJ, . Breastfeeding and maternal health outcomes: a systematic review and meta-analysis. Acta Paediatr. 2015;104(467):96–113. PMID: 26172878. 10.1111/apa.13102 26172878
53 Feltner C, Weber RP, Stuebe A, . Breastfeeding Programs and Policies, Breastfeeding Uptake, and Maternal Health Outcomes in Developed Countries. Comparative Effectiveness Review No. 2010. (Prepared by the RTI International–University of North Carolina at Chapel Hill Evidence-based Practice Center under Contract No. 290-2015-00011-I.). Rockville (MD): Agency for Healthcare Research and Quality (US); 2018. PMID: 3020437730204377.
54 Aune D, Norat T, Romundstad P, . Breastfeeding and the maternal risk of type 2 diabetes: a systematic review and dose-response meta-analysis of cohort studies. Nutr Metab Cardiovasc Dis. 2014;24(2):107–15. PMID: 24439841. 10.1016/j.numecd.2013.10.028 24439841
55 Dias CC and Figueiredo B. Breastfeeding and depression: a systematic review of the literature. J Affect Disord. 2015;171:142–54. PMID: 25305429. 10.1016/j.jad.2014.09.022 25305429
56 Centers for Disease Control and Prevention. Strategies to Prevent Obesity and Other Chronic Diseases: The CDC Guide to Strategies to Support Breastfeeding Mothers and Babies. Atlanta: U.S. Department of Health and Human Services; 2013. Available from: https://www.cdc.gov/breastfeeding/pdf/BF-Guide-508.PDF
57 Barraza L, Lebedevitch C and Steube A. The Role of Law and Policy in Assisting Families to Reach Healthy People’s Maternal, Infant, and Child Health Breastfeeding Goals in the United States. Department of Health and Human Services, Office of Disease Prevention and Health Promotion (ODPHP); 2020. Available from: https://www.healthypeople.gov/2020/law-and-health-policy/topic/maternal-infantchild-health.
58 American College of Obstetricians, Gynecologists’ Committee on Health Care for Underserved Women, American College of Obstetricians, . Barriers to Breastfeeding: Supporting Initiation and Continuation of Breastfeeding: ACOG Committee Opinion, Number 821. Obstet Gynecol. 2021;137(2):e54–e62. PMID: 33481532. 10.1097/AOG.0000000000004249 33481532
59 Office of the Surgeon General, Centers for Disease Control and Prevention (US) and Office on Women’s Health (US). The Surgeon General’s Call to Action to Support Breastfeeding. Rockville (MD): Office of the Surgeon General (US); 2011. PMID: 2145244821452448.
60 Baby Friendly USA Inc. About Us. The Baby-Friendly Hospital Initiative. 2023. Accessed May 12, 2023. Available from: https://www.babyfriendlyusa.org/about/
61 Baby Friendly USA Inc. The Ten Steps to Successful Breastfeeding. 10 Steps & International Code. 2023. Accessed May 12, 2023. Available from: https://www.babyfriendlyusa.org/for-facilities/practice-guidelines/10-steps-and-international-code/
62 World Health Organization. Protecting, promoting and supporting breastfeeding in facilities providing newborn services. Geneva: WHO; 2017. Available from: https://www.who.int/publications/i/item/9789241550086
63 Louis-Jacques A, Deubel TF, Taylor M, . Racial and ethnic disparities in U.S. breastfeeding and implications for maternal and child health outcomes. Semin Perinatol. 2017;41(5):299–307. PMID: 28624126. 10.1053/j.semperi.2017.04.007 28624126
64 Li R, Perrine CG, Anstey EH, . Breastfeeding Trends by Race/Ethnicity Among US Children Born From 2009 to 2015. JAMA Pediatr. 2019;173(12):e193319. PMID: 31609438. 10.1001/jamapediatrics.2019.3319 31609438
65 Jones KM, Power ML, Queenan JT, . Racial and ethnic disparities in breastfeeding. Breastfeed Med. 2015;10(4):186–96. PMID: 25831234. 10.1089/bfm.2014.0152 25831234
66 Bartkowski JP, Kohler J, Xu X, . Racial Differences in Breastfeeding on the Mississippi Gulf Coast: Making Sense of a Promotion-Prevalence Paradox with Cross-Sectional Data. Healthcare. 2022;10(12):03. PMID: 36553968. 10.3390/healthcare10122444 36553968
67 Standish KR and Parker MG. Social Determinants of Breastfeeding in the United States. Clin Ther. 2022;44(2):186–92. PMID: 34906370. 10.1016/j.clinthera.2021.11.010 34906370
68 Otarola L, Sly J, Manigat T, . Understanding Black Matriarchal Role Models in the U.S. Attitudes and Beliefs About Breastfeeding. Breastfeeding Medicine. 2021;16(6):501–5. PMID: 33769842. 10.1089/bfm.2020.0320 33769842
69 Gyamfi A, O’Neill B, Henderson WA, . Black/African American Breastfeeding Experience: Cultural, Sociological, and Health Dimensions Through an Equity Lens. Breastfeeding Medicine. 2021;16(2):103–11. PMID: 33591226. 10.1089/bfm.2020.0312 33591226
70 Callahan EH, Kim JH, Bahnfleth C, . Racial and Ethnic Disparities in Human Milk Feeding in the United States: A Rapid Review Project. Washington D.C., USA: U.S. Department of Agriculture, Food and Nutrition Service, Center for Nutrition Policy and Promotion, Nutrition Evidence Systematic Review; 2023. PMID.
71 Asiodu IV, Bugg K and Palmquist AEL. Achieving Breastfeeding Equity and Justice in Black Communities: Past, Present, and Future. Breastfeeding Medicine. 2021;16(6):447–51. PMID: 33979550. 10.1089/bfm.2020.0314 33979550
72 Gross TT, Powell R, Anderson AK, . WIC peer counselors’ perceptions of breastfeeding in African American women with lower incomes. J Hum Lact. 2015;31(1):99–110. PMID: 25480019. 10.1177/0890334414561061 25480019
73 Hinson TD, Skinner AC, Lich KH, . Factors That Influence Breastfeeding Initiation Among African American Women. J Obstet Gynecol Neonatal Nurs. 2018;47(3):290–300. PMID: 29550175. 10.1016/j.jogn.2018.02.007 29550175
74 Dauphin C, Clark N, Cadzow R, . #BlackBreastsMatter: Process Evaluation of Recruitment and Engagement of Pregnant African American Women for a Social Media Intervention Study to Increase Breastfeeding. J Med Internet Res. 2020;22(8):e16239. PMID: 32773377. 10.2196/16239 32773377
75 Mangun K PL. The Pet Milk Company “Happy Family” advertising campaign: a groundbreaking appeal to the Negro market of the 1950s. Journal Hist. 2014;40:70–84. 10.1080/00947679.2014.12062933
76 Hamner HC, Beauregard JL, Li R, . Meeting breastfeeding intentions differ by race/ethnicity, Infant and Toddler Feeding Practices Study-2. Matern Child Nutr. 2021;17(2):1–10. PMID: 33006242. 10.1111/mcn.13093 33006242
77 Rhodes EC, Damio G, LaPlant HW, . Promoting equity in breastfeeding through peer counseling: the US Breastfeeding Heritage and Pride program. Intern. 2021;20(1):128. PMID: 34044816. 10.1186/s12939-021-01408-3 34044816
78 Bunik M, Clark L, Zimmer LM, . Early infant feeding decisions in low-income Latinas. Breastfeed Med. 2006;1(4):225–35. PMID: 17661603. 10.1089/bfm.2006.1.225 17661603
79 Tran V, Reese Masterson A, Frieson T, . Barriers and facilitators to exclusive breastfeeding among Black mothers: A qualitative study utilizing a modified Barrier Analysis approach. Matern Child Nutr. 2023;19(1):e13428. PMID: 36098279. 10.1111/mcn.13428 36098279
80 Chang YS, Glaria AA, Davie P, . Breastfeeding experiences and support for women who are overweight or obese: A mixed-methods systematic review. Matern Child Nutr. 2020;16(1):e12865. PMID: 31240826. 10.1111/mcn.12865 31240826
81 Garner CD, McKenzie SA, Devine CM, . Obese women experience multiple challenges with breastfeeding that are either unique or exacerbated by their obesity: discoveries from a longitudinal, qualitative study. Matern Child Nutr. 2017;13(3): e12344. PMID: 27452978. 10.1111/mcn.12344 27452978
82 Amir LH and Donath S. A systematic review of maternal obesity and breastfeeding intention, initiation and duration. BMC Pregnancy Childbirth. 2007;7:9. PMID: 17608952. 10.1186/1471-2393-7-9 17608952
83 Bjorset VK, Helle C, Hillesund ER, . Socio-economic status and maternal BMI are associated with duration of breast-feeding of Norwegian infants. Public Health Nutr. 2018;21(8):1465–73. PMID: 29357963. 10.1017/S1368980017003925 29357963
84 Baker JL, Michaelsen KF, Sorensen TI, . High prepregnant body mass index is associated with early termination of full and any breastfeeding in Danish women. Am J Clin Nutr. 2007;86(2):404–11. PMID: 17684212. 10.1093/ajcn/86.2.404 17684212
85 Hales CM, Carroll MD, Fryar CD, . Prevalence of Obesity and Severe Obesity Among Adults: United States, 2017-2018. NCHS Data Brief. 2020(360):1–8. PMID: 32487284.32487284
86 Centers for Disease Control and Prevention. Obesity, Race/Ethnicity, and COVID-19. 2021. Accessed March 10, 2023. Available from: https://www.cdc.gov/obesity/downloads/data/obesity-maps/obesity-race-ethnicity-and-COVID-19-h.pdf
87 Claesson I-M, Larsson L, Steen L, . “You just need to leave the room when you breastfeed” Breastfeeding experiences among obese women in Sweden - A qualitative study. BMC Pregnancy Childbirth. 2018;18(1):39. PMID: 29357814. 10.1186/s12884-017-1656-2 29357814
88 Kair LR and Colaizy TT. Obese Mothers have Lower Odds of Experiencing Pro-breastfeeding Hospital Practices than Mothers of Normal Weight: CDC Pregnancy Risk Assessment Monitoring System (PRAMS), 2004-2008. Matern Child Health J. 2016;20(3):593–601. PMID: 26515471. 10.1007/s10995-015-1858-z 26515471
89 Griswold MK, Crawford SL, Perry DJ, . Experiences of Racism and Breastfeeding Initiation and Duration Among First-Time Mothers of the Black Women’s Health Study. J Racial Ethn Health Disparities. 2018;5(6):1180–91. PMID: 29435898. 10.1007/s40615-018-0465-2 29435898
90 Morris LL, J; Williams, JC. Exposed: descrimination against breastfeeding workers. San Francisco University of California, Hastings College of Law; 2019. PMID.
91 Kummer L, Duke N, Davis L, . Association of Social and Community Factors with U.S. Breastfeeding Outcomes. Breastfeeding Medicine. 2020;15(10):646–54. PMID: 32856942. 10.1089/bfm.2020.0083 32856942
92 Peregrino AB, Watt RG, Heilmann A, . Breastfeeding practices in the United Kingdom: Is the neighbourhood context important? Matern Child Nutr. 2018;14(4):1-. PMID: 29888866. 10.1111/mcn.12626 29888866
93 Lind JN, Perrine CG, Li R, . Racial disparities in access to maternity care practices that support breastfeeding - United States, 2011. MMWR Morb Mortal Wkly Rep. 2014;63(33):725–8. PMID: 25144543.25144543
94 Segura-Pérez S, Hromi-Fiedler A, Adnew M, . Impact of breastfeeding interventions among United States minority women on breastfeeding outcomes: a systematic review. Intern. 2021;20(1):1–25. PMID: 33676506. 10.1186/s12939-021-01388-4 33676506
95 Robinson K, Fial A and Hanson L. Racism, Bias, and Discrimination as Modifiable Barriers to Breastfeeding for African American Women: A Scoping Review of the Literature. J Midwifery Womens Health. 2019;64(6):734–42. PMID: 31710173. 10.1111/jmwh.13058 31710173
96 Thomas EV. “You Know if You Quit, That’s Failure, Right?”: Barriers to Professional Lactation Certification. J Hum Lact. 2018;34(3):454–66. PMID: 29852090. 10.1177/0890334418775062 29852090
97 Payne SL. A call to action: lactation equity through professional diversification. J Hum Lact. 2014;30(4):396–7. PMID: 25230770. 10.1177/0890334414550865 25230770
98 Perez-Escamilla R and Sellen D. Equity in breastfeeding: where do we go from here? J Hum Lact. 2015;31(1):12–4. PMID: 25583314. 10.1177/0890334414561062 25583314
99 Zamora G, Lutter CK and Pena-Rosas JP. Using an equity lens in the implementation of interventions to protect, promote, and support optimal breastfeeding practices. J Hum Lact. 2015;31(1):21–5. PMID: 25487074. 10.1177/0890334414561477 25487074
100 Evans K, Labbok M and Abrahams SW. WIC and breastfeeding support services: does the mix of services offered vary with race and ethnicity? Breastfeed Med. 2011;6(6):401–6. PMID: 21453123. 10.1089/bfm.2010.0086 21453123
101 Beal AC, Kuhlthau K and Perrin JM. Breastfeeding advice given to African American and white women by physicians and WIC counselors. Public Health Rep. 2003;118(4):368–76. PMID: 12815087. 10.1093/phr/118.4.368 12815087
102 Gallo S, Kogan K and Kitsantas P. Racial and Ethnic Differences in Reasons for Breastfeeding Cessation Among Women Participating in the Special Supplemental Nutrition Program for Women, Infants, and Children. J Midwifery Womens Health. 2019;64(6):725–33. PMID: 31469235. 10.1111/jmwh.13031 31469235
103 Johnson AM, Kirk R, Rooks AJ, . Enhancing Breastfeeding Through Healthcare Support: Results from a Focus Group Study of African American Mothers. Matern Child Health J. 2016;20(Suppl 1):92–102. PMID: 27449776. 10.1007/s10995-016-2085-y 27449776
104 Kulka TR, Jensen E, McLaurin S, . Community based participatory research of breastfeeding disparities in African American women. Infant Child Adolesc Nutr. 2011;3(4):233–9. PMID: 23326622. 10.1177/1941406411413918 23326622
105 Thomas EV. “Why Even Bother; They Are Not Going to Do It?” The Structural Roots of Racism and Discrimination in Lactation Care. Qual Health Res. 2018;28(7):1050–64. PMID: 29557297. 10.1177/1049732318759491 29557297
106 Vedam S, Stoll K, Taiwo TK, . The Giving Voice to Mothers study: inequity and mistreatment during pregnancy and childbirth in the United States. Reprod Health. 2019;16(1):77. PMID: 31182118. 10.1186/s12978-019-0729-2 31182118
107 Knox-Kazimierczuk FA, Nommsen-Rivers L, Ware J, . Exploring the Breastfeeding Experiences of African American Mothers Through a Critical Race Theory Lens. Breastfeeding Medicine. 2021;16(6):487–92. PMID: 33979549. 10.1089/bfm.2020.0328 33979549
108 Yourkavitch J and Hall Smith P. Women’s status, breastfeeding support, and breastfeeding practices in the United States. PLoS ONE. 2022;17(9):e0275021. PMID: 36170292. 10.1371/journal.pone.0275021 36170292
109 Eisenberg SR, Bair-Merritt MH, Colson ER, . Maternal Report of Advice Received for Infant Care. Pediatrics. 2015;136(2):e315–22. PMID: 26216322. 10.1542/peds.2015-0551 26216322
110 United Nations Development Programme. Human Development Report 2019. Beyond income, beyond averages, beyond today: Inequalities in human development in the 21st century. New York, NY: UNDP (United Nations Development Programme); 2019. Available from: https://hdr.undp.org/content/human-development-report-2019
111 Higgins JPT, Savović J, Page MJ, . Chapter 8: Assessing risk of bias in a randomized trial. In: Higgins JPT, Thomas J, Chandler J, Cumpston M, Li T, Page MJ, Welch VA (editors). Cochrane Handbook for Systematic Reviews of Interventions version 6.3 (updated February 2022). 2022. Available from: http://www.training.cochrane.org/handbook.
112 United States Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2021. Available from: https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes#methods.
113 Hartung J and Knapp G. A refined method for the meta-analysis of controlled clinical trials with binary outcome. Stat Med. 2001;20(24):3875–89. PMID: 11782040. 10.1002/sim.1009 11782040
114 U.S. Department of Health and Human Services. Healthy People 2030: Building a Healthier Future for All. Office of Disease Prevention and Health Promotion; 2023. Available from: https://health.gov/healthypeople.
115 Adams G, Gulliford MC, Ukoumunne OC, . Patterns of intra-cluster correlation from primary care research to inform study design and analysis. J Clin Epidemiol. 2004;57(8):785–94. PMID: 15485730. 10.1016/j.jclinepi.2003.12.013 15485730
116 Higgins J, Eldridge S and Li T. Chapter 23: Including variants on randomized trials. In: Higgins J, Thomas J, Chandler J, Cumpston M, Li T, Page M, ., editors. Cochrane Handbook for Systematic Reviews of Interventions version 6.3 (updated February 2022): Cochrane, 2022. Available from: 10.1002/sim.1186
117 Higgins JP and Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539–58. PMID: 12111919. 10.1002/sim.1186 12111919
118 Higgins J. Cochrane Handbook for Systematic Reviews of Interventions version 6.3 (updated February 2022). Higgins JPT, Thomas J, Chandler J, Cumpston M, Li T, Page MJ, ., editors. Cochrane, 2022. Available from: http://www.training.cochrane.org/handbook.
119 Peters JL, Sutton AJ, Jones DR, . Comparison of two methods to detect publication bias in meta-analysis. Jama. 2006;295(6):676–80. PMID: 16467236. 10.1001/jama.295.6.676 16467236
120 Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. p. 314–49.
121 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
122 Abbass-Dick J, Stern SB, Nelson LE, . Coparenting breastfeeding support and exclusive breastfeeding: a randomized controlled trial. Pediatrics. 2015;135(1):102–10. PMID: 254525653. 10.1542/peds.2014-1416 25452653
123 Abbass-Dick J, Sun W, Newport A, . The comparison of access to an eHealth resource to current practice on mother and co-parent teamwork and breastfeeding rates: A randomized controlled trial. Midwifery. 2020;90:102812. PMID: 32739716. 10.1016/j.midw.2020.102812 32739716
124 Acar Z and Sahin N. Development of a mobile application-based breastfeeding program and evaluation of its effectiveness. J Pediatr Nurs. 2024;74:51–60. PMID: 37995477. 10.1016/j.pedn.2023.11.011 37995477
125 Addicks SH and McNeil DW. Randomized Controlled Trial of Motivational Interviewing to Support Breastfeeding Among Appalachian Women. J Obstet Gynecol Neonatal Nurs. 2019;48(4):418–32. PMID: 31181186. 10.1016/j.jogn.2019.05.003 31181186
126 Anderson AK, Damio G, Young S, . A randomized trial assessing the efficacy of peer counseling on exclusive breastfeeding in a predominantly Latina low-income community. Arch Pediatr Adolesc Med. 2005;159(9):836–41. PMID: 16143742. 10.1001/archpedi.159.9.836 16143742
127 Balaguer Martinez J, Valcarce PI, Esquivel OJ, . Telephone support for breastfeeding by primary care: a randomised multicentre trial. Anales de pediatria (barcelona, spain : 2003). 2018;89(6):344–51. PMID: 29576447. 10.1016/j.anpedi.2018.02.007 29576447
128 Baransel ES and Caliskan BE. Effects of Face-to-Face Education Followed by Mobile Messaging to Primiparas on Maternal-Neonatal Care, Breastfeeding, and Motherhood Experience: A Randomized Controlled Trial. Z Geburtshilfe Neonatol. 2024;29:29. PMID: 38286412. 10.1055/a-2222-6568 38286412
129 Bender W, Levine L and Durnwald C. Text Message-Based Breastfeeding Support Compared With Usual Care: A Randomized Controlled Trial. Obstet Gynecol. 2022;140(5):853–60. PMID: 36201773. 10.1097/aog.0000000000004961 36201773
130 Bernal D. The effect of a peer counseling support program on breastfeeding initiation, duration and exclusivity among low-income Hispanic women. Marybelle and S. Paul Musco School of Nursing and Health Professions. Irvine, CA (USA): Brandman University; 2018.
131 Bonuck K, Stuebe A, Barnett J, . Effect of primary care intervention on breastfeeding duration and intensity (BINGO). Am J Public Health. 2014_a;104 Suppl 1:S119–27. PMID: 24354834. 10.2105/AJPH.2013.301360 24354834
132 Bonuck K, Stuebe A, Barnett J, . Effect of primary care intervention on breastfeeding duration and intensity (PAIRINGS). Am J Public Health. 2014_b;104 Suppl 1:S119–27. PMID: 24354834. 10.2105/AJPH.2013.301360 24354834
133 Bonuck KA, Freeman K and Trombley M. Randomized controlled trial of a prenatal and postnatal lactation consultant intervention on infant health care use. Arch Pediatr Adolesc Med. 2006;160(9):953–60. PMID: 16953019. 10.1001/archpedi.160.9.953 16953019
134 Bunik M, Jimenez-Zambrano A, Solano M, . Mother’s Milk Messaging TM: trial evaluation of app and texting for breastfeeding support. BMC Pregnancy Childbirth. 2022;22(1):660. PMID: 36002798. 10.1186/s12884-022-04976-6 36002798
135 Bunik M, Shobe P, O’Connor ME, . Are 2 weeks of daily breastfeeding support insufficient to overcome the influences of formula? Acad Pediatr. 2010;10(1):21–8. PMID: 20129478. 10.1016/j.acap.2009.09.014 20129478
136 Cangol E and Sahin NH. The Effect of a Breastfeeding Motivation Program Maintained During Pregnancy on Supporting Breastfeeding: A Randomized Controlled Trial. Breastfeed Med. 2017;12:218–26. PMID: 28287819. 10.1089/bfm.2016.0190 28287819
137 Carlsen EM, Kyhnaeb A, Renault KM, . Telephone-based support prolongs breastfeeding duration in obese women: a randomized trial. Am J Clin Nutr. 2013;95(2):1226–32. PMID: 24004897. 10.3945/ajcn.113.059600 24004897
138 Cauble JS, Herman A, Wick J, . A prenatal group based phone counseling intervention to improve breastfeeding rates and complementary feeding: a randomized, controlled pilot and feasibility trial. BMC Pregnancy Childbirth. 2021;21(1):521. PMID: 34294051. 10.1186/s12884-021-03976-2 34294051
139 Chan MY, Ip WY and Choi KC. The effect of a self-efficacy-based educational programme on maternal breast feeding self-efficacy, breast feeding duration and exclusive breast feeding rates: A longitudinal study. Midwifery. 2016;36:92–8. PMID: 27106949. 10.1016/j.midw.2016.03.003 27106949
140 Chapman DJ, Morel K, Bermudez-Millan A, . Breastfeeding education and support trial for overweight and obese women: a randomized trial. Pediatrics. 2013;131(1):e162–70. PMID: 23209111. 10.1542/peds.2012-0688 23209111
141 Clarke JL, Ingram J, Johnson D, . The ABA intervention for improving breastfeeding initiation and continuation: Feasibility study results. Matern Child Nutr. 2020;16(1):e12907. PMID: 31793233. 10.1111/mcn.12907 31793233
142 Dennis CL, Hodnett E, Gallop R, . The effect of peer support on breast-feeding duration among primiparous women: a randomized controlled trial. CMAJ. 2002;166(1):21–8. PMID: 11800243.11800243
143 Di Meglio G, McDermott MP and Klein JD. A randomized controlled trial of telephone peer support’s influence on breastfeeding duration in adolescent mothers. Breastfeed Med. 2010;5(1):41–7. PMID: 20043705. 10.1089/bfm.2009.0016 20043705
144 Di Napoli A, Di Lallo D, Fortes C, . Home breastfeeding support by health professionals: findings of a randomized controlled trial in a population of Italian women. Acta Paediatr. 2004;93(8):1108–14. PMID: 15456204.15456204
145 Edwards RC, Thullen MJ, Korfmacher J, . Breastfeeding and complementary food: randomized trial of community doula home visiting. Pediatrics. 2013;132 Suppl 2:S160–6. PMID: 24187119. 10.1542/peds.2013-1021P 24187119
146 Elliott-Rudder M, Pilotto L, McIntyre E, . Motivational interviewing improves exclusive breastfeeding in an Australian randomised controlled trial. Acta Paediatr. 2014;103(1):e11–6. PMID: 24117857. 10.1111/apa.12434 24117857
147 Fan HSL, Ho MY, Ko RWT, . Feasibility and effectiveness of WhatsApp online group on breastfeeding by peer counsellors: a single-blinded, open-label pilot randomized controlled study. Int Breastfeed J. 2022;17(1):91. PMID: 36544208. 10.1186/s13006-022-00535-z 36544208
148 Fiks AG, Gruver RS, Bishop-Gilyard CT, . A Social Media Peer Group for Mothers To Prevent Obesity from Infancy: The Grow2Gether Randomized Trial. Child. 2017;13(5):356–68. PMID: 28557558. 10.1089/chi.2017.0042 28557558
149 Forster D, McLachlan H, Lumley J, . Two mid-pregnancy interventions to increase the initiation and duration of breastfeeding: a randomized controlled trial. Birth. 2004;31(3):176–82. PMID: 15330879. 10.1111/j.0730-7659.2004.00302.x 15330879
150 Forster DA, McLardie-Hore FE, McLachlan HL, . Proactive Peer (Mother-to-Mother) Breastfeeding Support by Telephone (Ringing up About Breastfeeding Early [RUBY]): A Multicentre, Unblinded, Randomised Controlled Trial. EClinicalMedicine. 2019;8:20–8. PMID: 31193656. 10.1016/j.eclinm.2019.02.003 31193656
151 Franco-Antonio C, Calderon-Garcia JF, Santano-Mogena E, . Effectiveness of a brief motivational intervention to increase the breastfeeding duration in the first 6 months postpartum: Randomized controlled trial. J Adv Nurs. 2020;76(3):888–902. PMID: 31782535. 10.1111/jan.14274 31782535
152 Fu I, Fong D, Heys M, . Professional breastfeeding support for first-time mothers: a multicentre cluster randomised controlled trial. Bjog. 2014;121(13):1673–83. PMID: 24861802. 10.1111/1471-0528.12884 24861802
153 Gagnon AJ, Dougherty G, Jimenez V, . Randomized trial of postpartum care after hospital discharge. Pediatrics. 2002;109(6):1074–80. PMID: 12042545. 10.1542/peds.109.6.1074 12042545
154 Gijsbers B, Mesters I, Knottnerus JA, . The Success of an Educational Program to Promote Exclusive Breastfeeding for 6 Months in Families with a History of Asthma: A Randomized Controlled Trial. Pediatric Asthma, Allergy & Immunology. 2006;19(4):214–22. 10.1089/pai.2006.19.214
155 Graffy J, Taylor J, Williams A, . Randomised controlled trial of support from volunteer counsellors for mothers considering breast feeding. Bmj. 2004;328(7430):26. PMID: 14703543. 10.1136/bmj.328.7430.26 14703543
156 Gross RS, Mendelsohn AL, Gross MB, . Randomized Controlled Trial of a Primary Care-Based Child Obesity Prevention Intervention on Infant Feeding Practices. Journal of Pediatrics. 2016;174:171–7.e2. PMID: 27113376. 10.1016/j.jpeds.2016.03.060 27113376
157 Hans SL, Edwards RC and Zhang Y. Randomized Controlled Trial of Doula-Home-Visiting Services: Impact on Maternal and Infant Health. Maternal & Child Health Journal. 2018;22(Suppl 1):105–13. PMID: 29855838. 10.1007/s10995-018-2537-7 29855838
158 Henderson A, Stamp G and Pincombe J. Postpartum positioning and attachment education for increasing breastfeeding: a randomized trial. Birth. 2001;28(4):236–42. PMID: 11903211. 10.1046/j.1523-536x.2001.00236.x 11903211
159 Hoffmann J, Gunther J, Stecher L, . Effects of a lifestyle intervention in routine care on short-and long-term maternal weight retention and breastfeeding behavior - 12 months follow-up of the cluster-randomized gelis trial. J. 2019;8(6):876. PMID: 31248138. 10.3390/jcm8060876 31248138
160 Hopkinson J and Konefal Gallagher M. Assignment to a hospital-based breastfeeding clinic and exclusive breastfeeding among immigrant Hispanic mothers: a randomized, controlled trial. J Hum Lact. 2009;25(3):287–96. PMID: 19436060. 10.1177/0890334409335482 19436060
161 Howell EA, Bodnar-Deren S, Balbierz A, . An intervention to extend breastfeeding among black and Latina mothers after delivery. Am J Obstet Gynecol. 2014;210(3):239.e1–5. PMID: 24262719. 10.1016/j.ajog.2013.11.028 24262719
162 Jolly K, Ingram L, Freemantle N, . Effect of a peer support service on breast-feeding continuation in the UK: A randomised controlled trial. Midwifery. 2012;28(6):740–5. PMID: 21944571. 10.1016/j.midw.2011.08.005 21944571
163 Karaahmet AY and Bilgic FS. Breastfeeding success in the first 6 months of online breastfeeding counseling after cesarean delivery and its effect on anthropometric measurements of the baby: a randomized controlled study. Rev Assoc Med Bras. 2022;68(10):1434–40. PMID: 36417649. 10.1590/1806-9282.20220540 36417649
164 Kellams AL, Gurka KK, Hornsby PP, . The Impact of a Prenatal Education Video on Rates of Breastfeeding Initiation and Exclusivity during the Newborn Hospital Stay in a Low-income Population. J Hum Lact. 2015. PMID: 26289058. 10.1177/0890334415599402 26289058
165 Kenyon S, Jolly K, Hemming K, . Lay support for pregnant women with social risk: a randomised controlled trial. BMJ Open. 2016;6(3):e009203. PMID: 26936901. 10.1136/bmjopen-2015-009203 26936901
166 Kools EJ, Thijs C, Kester AD, . A breast-feeding promotion and support program a randomized trial in The Netherlands. Prev Med. 2005;40(1):60–70. PMID: 15530582. 10.1016/j.ypmed.2004.05.013 15530582
167 Kronborg H, Maimburg RD and Vaeth M. Antenatal training to improve breast feeding: a randomised trial. Midwifery. 2012;28(6):784–90. PMID: 22018394. 10.1016/j.midw.2011.08.016 22018394
168 Labarere J, Bellin V, Fourny M, . Assessment of a structured in-hospital educational intervention addressing breastfeeding: a prospective randomised open trial. Bjog. 2003;110(9):847–52. PMID: 14511968. 10.1111/j.1471-0528.2003.02539.x 14511968
169 Labarere J, Gelbert-Baudino N, Ayral AS, . Efficacy of breastfeeding support provided by trained clinicians during an early, routine, preventive visit: a prospective, randomized, open trial of 226 mother-infant pairs. Pediatrics. 2005;115(2):e139–e46. PMID: 15687421. 10.1542/peds.2004-1362 15687421
170 Laliberte C, Dunn S, Pound C, . A randomized controlled trial of innovative postpartum care model for mother-baby dyads. PLoS ONE. 2016;11(2): e0148520. PMID: 26871448. 10.1371/journal.pone.0148520 26871448
171 Lavender T, Baker L, Smyth R, . Breastfeeding expectations versus reality: a cluster randomised controlled trial. Bjog. 2005;112(8):1047–53. PMID: 16045516. 10.1111/j.1471-0528.2005.00644.x 16045516
172 Lewkowitz AK, Lopez JD, Carter EB, . Impact of a novel smartphone application on low-income, first-time mothers’ breastfeeding rates: a randomized controlled trial. Am J Obstet Gynecol MFM. 2020;2(3):100143. PMID: 33345878. 10.1016/j.ajogmf.2020.100143 33345878
173 Lewkowitz AK, Lopez JD, Stein RI, . Effect of a Home-Based Lifestyle Intervention on Breastfeeding Initiation Among Socioeconomically Disadvantaged African American Women with Overweight or Obesity. Breastfeed Med. 2018;13(6):418–25. PMID: 29912571. 10.1089/bfm.2018.0006 29912571
174 Linares AM, Cartagena D and Rayens MK. Las Dos Cosas Versus Exclusive Breastfeeding: A Culturally and Linguistically Exploratory Intervention Study in Hispanic Mothers Living in Kentucky. Journal of Pediatric Health Care. 2019;33(6):e46–e56. PMID: 31655788. 10.1016/j.pedhc.2019.07.009 31655788
175 Little EE, Cioffi CC, Bain L, . An Infant Carrier Intervention and Breastfeeding Duration: A Randomized Controlled Trial. Pediatrics. 2021;148(1):07. PMID: 34193622. 10.1542/peds.2020-049717 34193622
176 Lucas R, Zhang Y, Walsh SJ, . Efficacy of a Breastfeeding Pain Self-Management Intervention: A Pilot Randomized Controlled Trial. Nursing Research. 2019;68(2):E1–E10. PMID: 30829925. 10.1097/NNR.0000000000000336 30829925
177 Lutenbacher M, Elkins T and Dietrich MS. Using Community Health Workers to Improve Health Outcomes in a Sample of Hispanic Women and Their Infants: Findings from a Randomized Controlled Trial. Hisp Health Care Int. 2023;21(3):129–41. PMID: 35702003. 10.1177/15404153221107680 35702003
178 Mattar CN, Chong YS, Chan YS, . Simple antenatal preparation to improve breastfeeding practice: a randomized controlled trial. Obstet Gynecol. 2007;109(1):73–80. PMID: 17197590. 10.1097/01.AOG.0000249613.15466.26 17197590
179 McDonald SJ, Henderson JJ, Faulkner S, . Effect of an extended midwifery postnatal support programme on the duration of breast feeding: a randomised controlled trial. Midwifery. 2010;26(1):88–100. PMID: 18486287. 10.1016/j.midw.2008.03.001 18486287
180 McLachlan HL, Forster DA, Amir LH, . Supporting breastfeeding In Local Communities (SILC) in Victoria, Australia: a cluster randomised controlled trial. BMJ Open. 2016;6(2):e008292. PMID: 26832427. 10.1136/bmjopen-2015-008292 26832427
181 McQueen KA, Dennis CL, Stremler R, . A pilot randomized controlled trial of a breastfeeding self-efficacy intervention with primiparous mothers. J Obstet Gynecol Neonatal Nurs. 2011;40(1):35–46. PMID: 21244493. 10.1111/j.1552-6909.2010.01210.x 21244493
182 Milinco M, Travan L, Cattaneo A, . Effectiveness of biological nurturing on early breastfeeding problems: a randomized controlled trial. Int Breastfeed J. 2020;15(1):21. PMID: 32248838. 10.1186/s13006-020-00261-4 32248838
183 Miremberg H, Yirmiya K, Rona S, . Smartphone-based counseling and support platform and the effect on postpartum lactation: a randomized controlled trial. Am J Obstet Gynecol MFM. 2022;4(2):100543. PMID: 34871782. 10.1016/j.ajogmf.2021.100543 34871782
184 Mottl-Santiago J, Dukhovny D, Cabral H, . Effectiveness of an Enhanced Community Doula Intervention in a Safety Net Setting: A Randomized Controlled Trial. Health Equity. 2023;7(1):466–76. PMID: 37731785. 10.1089/heq.2022.0200 37731785
185 Muirhead PE, Butcher G, Rankin J, . The effect of a programme of organised and supervised peer support on the initiation and duration of breastfeeding: a randomised trial. Br J Gen Pract. 2006;56(524):191–7. PMID: 16536959. None16536959
186 Nilsson IMS, Strandberg-Larsen K, Knight CH, . Focused breastfeeding counselling improves short- and long-term success in an early-discharge setting: A cluster-randomized study. Matern Child Nutr. 2017;13(4):10. PMID: 28194877. 10.1111/mcn.12432 28194877
187 Noel-Weiss J, Rupp A, Cragg B, . Randomized controlled trial to determine effects of prenatal breastfeeding workshop on maternal breastfeeding self-efficacy and breastfeeding duration. J Obstet Gynecol Neonatal Nurs. 2006;35(5):616–24. PMID: 16958717. 10.1111/j.1552-6909.2006.00077.x 16958717
188 O’Reilly SL, McNestry C, McGuinness D, . Multicomponent perinatal breastfeeding support in women with BMI >25: The Latch On multi-centre randomised trial. BJOG: An International Journal of Obstetrics & Gynaecology. 2024;12:12. PMID: 38344894. 10.1111/1471-0528.17782 38344894
189 Paul IM, Beiler JS, Schaefer EW, . A randomized trial of single home nursing visits vs office-based care after nursery/maternity discharge: the Nurses for Infants Through Teaching and Assessment After the Nursery (NITTANY) Study. Arch Pediatr Adolesc Med. 2012;166(3):263–70. PMID: 22064874. 10.1001/archpediatrics.2011.198 22064874
190 Pollard DL. Impact of a feeding log on breastfeeding duration and exclusivity. Matern Child Health J. 2011;15(3):395–400. PMID: 20177755. 10.1007/s10995-010-0583-x 20177755
191 Puharic D, Malicki M, Borovac JA, . The effect of a combined intervention on exclusive breastfeeding in primiparas: A randomised controlled trial. Matern Child Nutr. 2020;16(3):e12948. PMID: 31943761. 10.1111/mcn.12948 31943761
192 Quinlivan JA, Box H and Evans SF. Postnatal home visits in teenage mothers: a randomised controlled trial. Lancet. 2003;361(9361):893–900. PMID: 12648967. 10.1016/S0140-6736(03)12770-5 12648967
193 Reeder JA, Joyce T, Sibley K, . Telephone peer counseling of breastfeeding among WIC participants: a randomized controlled trial. Pediatrics. 2014;134(3):e700–9. PMID: 25092936. 10.1542/peds.2013-4146 25092936
194 Saglik M and Karacam Z. Effectiveness of structured education and follow-up in the management of perceived breastmilk insufficiency: a randomized control trial. Health Care Women Int. 2021;44(3):276–94. PMID: 34919025. 10.1080/07399332.2021.2007249 34919025
195 Santamaria-Martin MJ, Martin-Iglesias S, Schwarz C, . Effectiveness of a group educational intervention - prolact - in primary care to promote exclusive breastfeeding: a cluster randomized clinical trial. BMC Pregnancy Childbirth. 2022;22(1):132. PMID: 35172775. 10.1186/s12884-022-04394-8 35172775
196 Sari C and Altay N. Effects of providing nursing care with web-based program on maternal self-efficacy and infant health. Public Health Nurs. 2020;37(3):380–92. PMID: 32017251. 10.1111/phn.12712 32017251
197 Sari Ozturk C and Demir K. The Effect of Mandala Activity and Technology-Based Breastfeeding Program on Breastfeeding Self-Efficacy and Mother-Infant Attachment of Primiparous Women: A Randomized Controlled Study. J Med Syst. 2023;47(1):44. PMID: 37004692. 10.1007/s10916-023-01942-3 37004692
198 Saucedo Baza A, Mignacca C, Delgado PE, . A Technological Approach to Improved Breastfeeding Rates and Self-Efficacy: A Randomized Controlled Pilot Study. J Hum Lact. 2023;39(4):679–87. PMID: 37571838. 10.1177/08903344231190625 37571838
199 Schwarz EB, Hoyt-Austin A, Fix M, . Prenatal Counseling on the Maternal Health Benefits of Lactation: A Randomized Trial. Breastfeed Med. 2024;19(1):52–8. PMID: 38190278. 10.1089/bfm.2023.0219 38190278
200 Sevda KO and Sevil I. Continuous Lactation Support Provided Through the WhatsApp Messaging Application: A Randomized Controlled Trial. J Hum Lact. 2023;39(4):666–78. PMID: 37646262. 10.1177/08903344231192948 37646262
201 Simsek-Cetinkaya S, Gumus Calis G and Kibris S. Effect of Breastfeeding Education Program and Nurse-led Breastfeeding Online Counseling System (BMUM) for Mothers: A Randomized Controlled Study. J Hum Lact. 2024;40(1):101–12. PMID: 38006250. 10.1177/08903344231210813 38006250
202 Stockdale J, Sinclair M, Kernohan WG, . Feasibility study to test DESIGNER BREASTFEEDING: a randomised controlled trial. Evidence Based Midwifery. 2008;6(3):76–82.
203 Su LL, Chong YS, Chan YH, . Antenatal education and postnatal support strategies for improving rates of exclusive breast feeding: randomised controlled trial. Bmj. 2007;335(7620):596. PMID: 17670909. 10.1136/bmj.39279.656343.55 17670909
204 Taylor B, Gray A, Galland B, . Targeting sleep, food, and activity in infants for obesity prevention: an RCT. Pediatrics. 2017;139(3):e20162037. PMID: 28242860. 10.1542/peds.2016-2037 28242860
205 Uscher-Pines L, Ghosh-Dastidar B, Bogen DL, . Feasibility and Effectiveness of Telelactation Among Rural Breastfeeding Women. Academic pediatrics. 2020;20(5):652–9. PMID: 31629118. 10.1016/j.acap.2019.10.008 31629118
206 Wallace LM, Dunn OM, Alder EM, . A randomised-controlled trial in England of a postnatal midwifery intervention on breast-feeding duration. Midwifery. 2006;22(3):262–73. PMID: 16380197. 10.1016/j.midw.2005.06.004 16380197
207 Wambach KA, Aaronson L, Breedlove G, . A randomized controlled trial of breastfeeding support and education for adolescent mothers. West J Nurs Res. 2011;33(4):486–505. PMID: 20876551. 10.1177/0193945910380408 20876551
208 Wen LM, Baur LA, Simpson JM, . Effectiveness of an early intervention on infant feeding practices and “tummy time”: a randomized controlled trial. Arch Pediatr Adolesc Med. 2011;165(8):701–7. PMID: 21810633. 10.1001/archpediatrics.2011.115 21810633
209 Wen LM, Rissel C, Xu H, . Effects of Telephone and Short Message Service Support on Infant Feeding Practices, “Tummy Time,” and Screen Time at 6 and 12 Months of Child Age: A 3-Group Randomized Clinical Trial. JAMA Pediatrics. 2020;174(7):657–64. PMID: 32282034. 10.1001/jamapediatrics.2020.0215 32282034
210 Wong KL, Tak Fong DY, Yin Lee IL, . Antenatal education to increase exclusive breastfeeding: a randomized controlled trial. Obstet Gynecol. 2014;124(5):961–8. PMID: 25437725. 10.1097/AOG.0000000000000481 25437725
211 Yesil Y, Ekşioğlu A and Turfan EC. The effect of hospital-based breastfeeding group education given early perinatal period on breastfeeding self-efficacy and breastfeeding status. Journal of Neonatal Nursing. 2023;29(1):81–90. PMID: None. 10.1016/j.jnn.2022.02.013
212 Abbass-Dick J. Evaluating the effectiveness of a coparenting breastfeeding support intervention (COSI) on exclusive breastfeeding rates at twelve weeks postpartum. Nursing Science. Toronto, Canada: Lawrence S. Bloomberg Faculty of Nursing University of Toronto; 2013.
213 Bonuck KA, Trombley M, Freeman K, . Randomized, controlled trial of a prenatal and postnatal lactation consultant intervention on duration and intensity of breastfeeding up to 12 months. Pediatrics. 2005;116(6):1413–26. PMID: 16322166. 10.1542/peds.2005-0435 16322166
214 Cahill AG, Haire-Joshu D, Cade WT, . Weight Control Program and Gestational Weight Gain in Disadvantaged Women with Overweight or Obesity: A Randomized Clinical Trial. Obesity (Silver Spring). 2018;26(3):485–91. PMID: 29464907. 10.1002/oby.22070 29464907
215 Ekambareshwar M, Mihrshahi S, Wen LM, . Facilitators and challenges in recruiting pregnant women to an infant obesity prevention programme delivered via telephone calls or text messages. Trials. 2018;19(1):494. PMID: 30219067. 10.1186/s13063-018-2871-5 30219067
216 Forster D, McLachlan H, Davey M-A, . Ringing Up about Breastfeeding: a randomised controlled trial exploring early telephone peer support for breastfeeding (RUBY) – trial protocol. BMC Pregnancy Childbirth. 2014;177. PMID: 24886264. 10.1186/1471-2393-14-177 24886264
217 Franco-Antonio C, Calderon-Garcia JF, Vilar-Lopez R, . A randomized controlled trial to evaluate the effectiveness of a brief motivational intervention to improve exclusive breastfeeding rates: Study protocol. J Adv Nurs. 2018;75(4):888–97. PMID: 30478855. 10.1111/jan.13917 30478855
218 Franco-Antonio C, Santano-Mogena E, Chimento-Diaz S, . A randomised controlled trial evaluating the effect of a brief motivational intervention to promote breastfeeding in postpartum depression. Sci. 2022;12(1):373. PMID: 35013506. 10.1038/s41598-021-04338-w 35013506
219 Griffin LB, Lopez JD, Ranney ML, . Effect of Novel Breastfeeding Smartphone Applications on Breastfeeding Rates. Breastfeed Med. 2021;16(8):614–23. PMID: 33826418. 10.1089/bfm.2021.0012 33826418
220 Grimes HA, Forster DA, Shafiei T, . Breastfeeding peer support by telephone in the RUBY randomised controlled trial: A qualitative exploration of volunteers’ experiences. PLoS ONE. 2020;15(8):e0237190. PMID: 32760148. 10.1371/journal.pone.0237190 32760148
221 Grimes HA, McLachlan HL, Forster DA, . Implementing a successful proactive telephone breastfeeding peer support intervention: volunteer recruitment, training, and intervention delivery in the RUBY randomised controlled trial. Int Breastfeed J. 2021;16(1):90. PMID: 34852839. 10.1186/s13006-021-00434-9 34852839
222 Grimes HA, Shafiei T, McLachlan HL, . Volunteers’ experiences of providing telephone-based breast-feeding peer support in the RUBY randomised controlled trial. Public Health Nutr. 2020;23(16):3005–15. PMID: 32600489. 10.1017/S136898002000124X 32600489
223 Gruver RS, Bishop-Gilyard CT, Lieberman A, . A Social Media Peer Group Intervention for Mothers to Prevent Obesity and Promote Healthy Growth from Infancy: Development and Pilot Trial. JMIR Res Protoc. 2016;5(3):e159. PMID: 27485934. 10.2196/resprot.5276 27485934
224 Günther J, Hoffmann J, Kunath J, . Effects of a Lifestyle Intervention in Routine Care on Prenatal Dietary Behavior-Findings from the Cluster-Randomized GeliS Trial. J Clin Med. 2019;8(7). PMID: 31269753. 10.3390/jcm8070960 31269753
225 Hoffmann J, Günther J, Geyer K, . Effects of a lifestyle intervention in routine care on prenatal physical activity - findings from the cluster-randomised GeliS trial. BMC Pregnancy Childbirth. 2019;19(1):414. PMID: 31711430. 10.1186/s12884-019-2553-7 31711430
226 Hornsby PP, Gurka KK, Conaway MR, . Reasons for Early Cessation of Breastfeeding Among Women with Low Income. Breastfeed Med. 2019;14(6):375–81. PMID: 30994371. 10.1089/bfm.2018.0206 30994371
227 Howell EA, Balbierz A, Wang J, . Reducing postpartum depressive symptoms among black and Latina mothers: a randomized controlled trial. Obstet Gynecol. 2012;119(5):942–9. PMID: 22488220. 10.1097/AOG.0b013e318250ba48 22488220
228 Jolly K, Ingram J, Clarke J, . Protocol for a feasibility trial for improving breast feeding initiation and continuation: assets-based infant feeding help before and after birth (ABA). BMJ Open. 2018;8(1):e019142. PMID: 29362263. 10.1136/bmjopen-2017-019142 29362263
229 Kellams AL, Gurka KK, Hornsby PP, . A Randomized Trial of Prenatal Video Education to Improve Breastfeeding Among Low-Income Women. Breastfeed Med. 2018;13(10):666–73. PMID: 30351169. 10.1089/bfm.2018.0115 30351169
230 Kunath J, Günther J, Rauh K, . Effects of a lifestyle intervention during pregnancy to prevent excessive gestational weight gain in routine care - the cluster-randomised GeliS trial. BMC Med. 2019;17(1):5. PMID: 30636636. 10.1186/s12916-018-1235-z 30636636
231 Lewkowitz AK, Lopez JD, Werner EF, . Effect of a Novel Smartphone Application on Breastfeeding Rates Among Low-Income, First-Time Mothers Intending to Exclusively Breastfeed: Secondary Analysis of a Randomized Controlled Trial. Breastfeed Med. 2021;16(1):59–67. PMID: 33085510. 10.1089/bfm.2020.0240 33085510
232 Lok KY, Ko RW, Fan HS, . Feasibility and Acceptability of an Online WhatsApp Support Group on Breastfeeding: Protocol for a Randomized Controlled Trial. JMIR Res Protoc. 2022;11(3):e32338. PMID: 35262504. 10.2196/32338 35262504
233 Lucchini-Raies C, Marquez-Doren F, Beca P, . The CRIAA Program complex intervention in primary care to support women and their families in breastfeeding: Study protocol for a pilot trial. J Adv Nurs. 2020;76(12):3641–53. PMID: 33058232. 10.1111/jan.14534 33058232
234 MacArthur C, Jolly K, Ingram L, . Antenatal peer support workers and initiation of breast feeding: Cluster randomised controlled trial. Bmj. 2009;338(7691):No Pagination Specified. PMID: 19181730. 10.1136/bmj.b131 19181730
235 Martin-Iglesias S, Santamaria-Martin MJ, Alonso-Alvarez A, . Effectiveness of an educational group intervention in primary healthcare for continued exclusive breast-feeding: PROLACT study. BMC Pregnancy Childbirth. 2018;18(1):59. PMID: 29482516. 10.1186/s12884-018-1679-3 29482516
236 McLachlan HL, Forster DA, Amir LH, . Supporting breastfeeding In Local Communities (SILC): protocol for a cluster randomised controlled trial. BMC Pregnancy Childbirth. 2014;14:346. PMID: 25281300. 10.1186/1471-2393-14-346 25281300
237 McLardie-Hore FE, McLachlan HL, Shafiei T, . Proactive telephone-based peer support for breastfeeding: a cross-sectional survey of women’s experiences of receiving support in the RUBY randomised controlled trial. BMJ Open. 2020;10(10):e040412. PMID: 33127637. 10.1136/bmjopen-2020-040412 33127637
238 Messito MJ, Katzow MW, Mendelsohn AL, . Starting Early Program Impacts on Feeding at Infant 10 Months Age: A Randomized Controlled Trial. Child. 2020;16:S-4–S-13. PMID: 31934788. 10.1089/chi.2019.0236 31934788
239 Mesters I, Gijsbers B, Bartholomew K, . Social cognitive changes resulting from an effective breastfeeding education program. Breastfeed Med. 2013;8(1):23–30. PMID: 23186384. 10.1089/bfm.2012.0011 23186384
240 Noel-Weiss J, Bassett V and Cragg B. Developing a prenatal breastfeeding workshop to support maternal breastfeeding self-efficacy. J Obstet Gynecol Neonatal Nurs. 2006;35(3):349–57. PMID: 16700684. 10.1111/j.1552-6909.2006.00053.x 16700684
241 O’Reilly SL, O’Brien EC, McGuinness D, . Latch On: A protocol for a multi-centre, randomised controlled trial of perinatal support to improve breastfeeding outcomes in women with a raised BMI. Contemp Clin Trials Commun. 2021;22:100767. PMID: 34095603. 10.1016/j.conctc.2021.100767 34095603
242 Rauh K, Kunath J, Rosenfeld E, . Healthy living in pregnancy: a cluster-randomized controlled trial to prevent excessive gestational weight gain - rationale and design of the GeliS study. BMC Pregnancy Childbirth. 2014;14:119. PMID: 24678761. 10.1186/1471-2393-14-119 24678761
243 Ridgway L, Cramer R, McLachlan HL, . Breastfeeding Support in the Early Postpartum: Content of Home Visits in the SILC Trial. Birth. 2016;43(4):303–12. PMID: 27417659. 10.1111/birt.12241 27417659
244 Wen LM, Baur LA, Rissel C, . Early intervention of multiple home visits to prevent childhood obesity in a disadvantaged population: a home-based randomised controlled trial (Healthy Beginnings Trial). BMC Public Health. 2007;7:76. PMID: 17490492. 10.1186/1471-2458-7-76 17490492
245 Wen LM, Rissel C, Baur LA, . A 3-Arm randomised controlled trial of Communicating Healthy Beginnings Advice by Telephone (CHAT) to mothers with infants to prevent childhood obesity. BMC Public Health. 2017;17(1):79. PMID: 28088203. 10.1186/s12889-016-4005-x 28088203
246 Zakarija-Grkovic I, Puharic D, Malicki M, . Breastfeeding booklet and proactive phone calls for increasing exclusive breastfeeding rates: RCT protocol. Matern Child Nutr. 2017;13(1):01. PMID: 26990672. 10.1111/mcn.12249 26990672
247 Baby Friendly USA Inc. Designation Process. The Baby-Friendly Hospital Initiative. 2023. Accessed May 12, 2023. Available from: https://www.babyfriendlyusa.org/for-facilities/designation-process/
248 Baby Friendly USA Inc. Upholding the Highest Standards of Infant Feeding Care. 2023. Accessed May 12, 2023. Available from: https://www.babyfriendlyusa.org/
249 Population Medicine. PROBIT Publication List. 2021. Accessed May 12, 2023. Available from: https://www.populationmedicine.org/sites/default/files/2021-02/PROBIT%20publications%20List_4%20Feb%202021.pdf
250 Martens PJ. What do Kramer’s Baby-Friendly Hospital Initiative PROBIT studies tell us? A review of a decade of research. J Hum Lact. 2012;28(3):335–42. PMID: 22584874. 10.1177/0890334412438264 22584874
251 Tomori C, Hernández-Cordero S, Busath N, . What works to protect, promote and support breastfeeding on a large scale: A review of reviews. Matern Child Nutr. 2022;18 Suppl 3(Suppl 3):e13344. PMID: 35315573. 10.1111/mcn.13344 35315573
252 Wouk K, Tully KP and Labbok MH. Systematic Review of Evidence for Baby-Friendly Hospital Initiative Step 3. J Hum Lact. 2017;33(1):50–82. PMID: 28135481. 10.1177/0890334416679618 28135481
253 Fallon VM, Harrold JA and Chisholm A. The impact of the UK Baby Friendly Initiative on maternal and infant health outcomes: A mixed-methods systematic review. Matern Child Nutr. 2019;15(3):e12778. PMID: 30623576. 10.1111/mcn.12778 30623576
254 Perez-Escamilla R, Martinez JL and Segura-Perez S. Impact of the Baby-friendly Hospital Initiative on breastfeeding and child health outcomes: a systematic review. Matern Child Nutr. 2016;12(3):402–17. PMID: 26924775. 10.1111/mcn.12294 26924775
255 Howe-Heyman A and Lutenbacher M. The Baby-Friendly Hospital Initiative as an Intervention to Improve Breastfeeding Rates: A Review of the Literature. J Midwifery Womens Health. 2016;61(1):77–102. PMID: 26801336. 10.1111/jmwh.12376 26801336
256 Bass JL, Gartley T and Kleinman R. Outcomes from the Centers for Disease Control and Prevention 2018 Breastfeeding Report Card: Public Policy Implications. Journal of Pediatrics. 2020;218:16-. PMID: 31623856. 10.1016/j.jpeds.2019.08.059 31623856
257 Advisory Board. Could the Baby-Friendly Hospital Initiative be hurting mothers—and babies too? Daily Briefing. 2023. Accessed May 12, 2023. Available from: https://www.advisory.com/daily-briefing/2020/01/13/baby-friendly
258 Gomez-Pomar E and Blubaugh R. The Baby Friendly Hospital Initiative and the ten steps for successful breastfeeding. a critical review of the literature. J Perinatol. 2018;38(6):623–32. PMID: 29416115. 10.1038/s41372-018-0068-0 29416115
259 Fed is Best Foundation. OUR MISSION: SAFE BREASTFEEDING AND BOTTLE-FEEDING SUPPORT. 2022. Accessed May 12, 2023. Available from: https://fedisbest.org/
260 Tully KP and Ball HL. Maternal accounts of their breast-feeding intent and early challenges after caesarean childbirth. Midwifery. 2014;30(6):712–9. PMID: 24252711. 10.1016/j.midw.2013.10.014 24252711
261 Hinsliff-Smith K, Spencer R and Walsh D. Realities, difficulties, and outcomes for mothers choosing to breastfeed: primigravid mothers experiences in the early postpartum period (6-8 weeks). Midwifery. 2014;30(1):e14–9. PMID: 24238980. 10.1016/j.midw.2013.10.001 24238980
262 Thomson G, Ebisch-Burton K and Flacking R. Shame if you do--shame if you don’t: women’s experiences of infant feeding. Matern Child Nutr. 2015;11(1):33–46. PMID: 25138617. 10.1111/mcn.12148 25138617
263 Hoddinott P, Craig LC, Britten J, . A serial qualitative interview study of infant feeding experiences: idealism meets realism. BMJ Open. 2012;2(2):e000504. PMID: 22422915. 10.1136/bmjopen-2011-000504 22422915
264 Thomson G and Dykes F. Women’s sense of coherence related to their infant feeding experiences. Matern Child Nutr. 2011;7(2):160–74. PMID: 21108741. 10.1111/j.1740-8709.2010.00251.x 21108741
265 U.S. Department of Agriculture. About WIC Breastfeeding Suppport. WIC Breastfeeding Suppport: USDA; 2023. Accessed May 15, 2023. Available from: https://wicbreastfeeding.fns.usda.gov/about
266 U.S. Department of Agriculture. Am I Eligible for WIC? Food and Nutrition Service: USDA; 2023. Accessed May 15, 2023. Available from: https://www.fns.usda.gov/wic
267 National WIC Association. WIC Program Overview and History. WIC Basics. 2018. Accessed May 21, 2023. Available from: https://www.nwica.org/overview-and-history
268 National Academies of Science E, and Medicine;. The WIC Food Packages: From Then to Now. NASEM; 2016. https://nap.nationalacademies.org/resource/23655/WIC-timeline.pdf
269 U.S. Department of Agriculture. WIC Eligibility Requirements. Food and Nutrition Service: USDA; 2023. Accessed May 12, 2023. Available from: https://www.fns.usda.gov/wic/wic-eligibility-requirements
270 U.S. Department of Agriculture. National and State Level Estimates of WIC Eligibility and Program Reach in 2020. Food and Nutrition Service: USDA; 2023. Accessed May 12, 2023. Available from: https://www.fns.usda.gov/research/wic/eligibility-program-reach-estimates-2020
271 American College of Obstetricians and Gynecologists. Committee Opinion No. 570: Breastfeeding in Underserved Women: Increasing Initiation and Continuation of Breastfeeding. Obstet Gynecol. 2013;122(2 PART 1):423–7. PMID: 23969829. 10.1097/01.AOG.0000433008.93971.6a 23969829
272 Parasuraman S, Lebrun-Harris L and Jones J. Breastfeeding Initiation, Duration, and Exclusivity Among WIC-Eligible Populations. Health Serv Res. 2020;55(S1):30–1. PMID. 10.1111/1475-6773.13366
273 Gleason S, Wilkin MK, Sallack L, . Breastfeeding Duration Is Associated With WIC Site-Level Breastfeeding Support Practices. J Nutr Educ Behav. 2020;52(7):680–7. PMID: 32171671. 10.1016/j.jneb.2020.01.014 32171671
274 Borger C, Weinfield NS, Paolicelli C, . Prenatal and Postnatal Experiences Predict Breastfeeding Patterns in the WIC Infant and Toddler Feeding Practices Study-2. Breastfeed Med. 2021;16(11):869–77. PMID: 34265220. 10.1089/bfm.2021.0054 34265220
275 Assibey-Mensah V, Suter B, Thevenet-Morrison K, . Effectiveness of Peer Counselor Support on Breastfeeding Outcomes in WIC-Enrolled Women. J Nutr Educ Behav. 2019;51(6):650–7. PMID: 30981656. 10.1016/j.jneb.2019.03.005 30981656
276 Caulfield LE, Bennett WL, Gross SM, . AHRQ Comparative Effectiveness Reviews. Maternal and Child Outcomes Associated With the Special Supplemental Nutrition Program for Women, Infants, and Children (WIC). Rockville (MD): Agency for Healthcare Research and Quality (US); 2022.
277 Paolicelli C, Berman D, Owens T, . Breastfeeding and Complementary Feeding Patterns Among Women Enrolled in WIC: WIC Infant and Toddler Feeding Practices Study-2. Breastfeed Med. 2017;12(8):482–6. PMID: 28829156. 10.1089/bfm.2017.0118 28829156
278 Gross SM, Lerman JL, Hurley KM, . Breastfeeding Outcomes Associated With the Special Supplemental Nutrition Program for Women, Infants, and Children: A Systematic Review. Acad Pediatr. 2023;23(2):244–60. PMID: 36272723. 10.1016/j.acap.2022.10.008 36272723
279 Li K, Wen M, Reynolds M, . WIC Participation and Breastfeeding after the 2009 WIC Revision: A Propensity Score Approach. Int J Environ Res Public Health. 2019;16(15). PMID: 31344937. 10.3390/ijerph16152645 31344937
280 Kogan K, Anand P, Gallo S, . A Quasi-Experimental Assessment of the Effect of the 2009 WIC Food Package Revisions on Breastfeeding Outcomes. Nutrients. 2023;15(2). PMID: 36678285. 10.3390/nu15020414 36678285
281 Nurse-Family Partnership. Home - About Us. Nurse-Family Partnershipt and Child First; 2023. Accessed May 12, 2023. Available from: https://www.nursefamilypartnership.org/about/
282 Maternal & Family Health Services. NFP Eligibility. MFHS; 2021. Accessed August 12, 2023. Available from: https://www.mfhs.org/programs/nurse-family-partnership/eligibility/
283 Bunik M, Krebs NF, Beaty B, . Breastfeeding and WIC enrollment in the Nurse Family Partnership Program. Breastfeed Med. 2009;4(3):145–9. PMID: 19243262. 10.1089/bfm.2008.0140 19243262
284 Miller TR. Projected Outcomes of Nurse-Family Partnership Home Visitation During 1996-2013, USA. Prev Sci. 2015;16(6):765–77. PMID: 26076883. 10.1007/s11121-015-0572-9 26076883
285 Healthcare.gov. Breastfeeding benefits. Health benefits & coverage. 2023. Accessed May 12, 2023. Available from: https://www.healthcare.gov/coverage/breast-feeding-benefits/
286 117th US Congress. H.R.3110 - PUMP for Nursing Mothers Act. 2021. Accessed May 12, 2023. Available from: https://www.congress.gov/bill/117th-congress/house-bill/3110
287 Damante B. 5 Facts About the PUMP for Nursing Mothers Act. Center for American Progress; 2023. Accessed May 12, 2023. Available from: https://www.americanprogress.org/article/5-facts-about-the-pump-for-nursing-mothers-act/
288 Gavine A, Shinwell SC, Buchanan P, . Support for healthy breastfeeding mothers with healthy term babies. Cochrane Database Syst Rev. 2022(10). PMID: 36282618. 10.1002/14651858.CD001141.pub6 36282618
289 Scott JA, Burns SK, Hauck YL, . Impact of a Face-To-Face Versus Smartphone App Versus Combined Breastfeeding Intervention Targeting Fathers: Randomized Controlled Trial. JMIR Pediatr Parent. 2021;4(2):e24579. PMID: 33843604. 10.2196/24579 33843604
290 Dagla M, Mrvoljak-Theodoropoulou I, Karagianni D, . Women’s Mental Health as a Factor Associated with Exclusive Breastfeeding and Breastfeeding Duration: Data from a Longitudinal Study in Greece. Children (Basel). 2021;8(2). PMID: 33671169. 10.3390/children8020150 33671169
291 Hoff CE, Movva N, Rosen Vollmar AK, . Impact of Maternal Anxiety on Breastfeeding Outcomes: A Systematic Review. Adv Nutr. 2019;10(5):816–26. PMID: 31079143. 10.1093/advances/nmy132 31079143
292 Labiner-Wolfe J, Fein SB, Shealy KR, . Prevalence of breast milk expression and associated factors. Pediatrics. 2008;122 Suppl 2:S63–8. PMID: 18829833. 10.1542/peds.2008-1315h 18829833
293 Geraghty SR and Rasmussen KM. Redefining “breastfeeding” initiation and duration in the age of breastmilk pumping. Breastfeed Med. 2010;5(3):135–7. PMID: 20433365. 10.1089/bfm.2009.0094 20433365
294 Committee on Nutrition. Donor Human Milk for the High-Risk Infant: Preparation, Safety, and Usage Options in the United States. Pediatrics. 2017;139(1). PMID: 27994111. 10.1542/peds.2016-3440 27994111
295 Kair LR, Flaherman VJ and Colaizy TT. Effect of Donor Milk Supplementation on Breastfeeding Outcomes in Term Newborns: A Randomized Controlled Trial. Clin Pediatr (Phila). 2019;58(5):534–40. PMID: 30688082. 10.1177/0009922819826105 30688082
296 Aarts C, Kylberg E, Hörnell A, . How exclusive is exclusive breastfeeding? A comparison of data since birth with current status data. Int J Epidemiol. 2000;29(6):1041–6. PMID: 11101545. 10.1093/ije/29.6.1041 11101545
297 Chapman DJ and Pérez-Escamilla R. US national breastfeeding monitoring and surveillance: current status and recommendations. J Hum Lact. 2009;25(2):139–50. PMID: 19286840. 10.1177/0890334409332437 19286840
298 Hector DJ. Complexities and subtleties in the measurement and reporting of breastfeeding practices. Int Breastfeed J. 2011;6:5. PMID: 21586109. 10.1186/1746-4358-6-5 21586109
299 Labbok MH and Starling A. Definitions of breastfeeding: call for the development and use of consistent definitions in research and peer-reviewed literature. Breastfeed Med. 2012;7(6):397–402. PMID: 23215907. 10.1089/bfm.2012.9975 23215907
300 Noel-Weiss J, Boersma S and Kujawa-Myles S. Questioning current definitions for breastfeeding research. Int Breastfeed J. 2012;7(1):9. PMID: 22889093. 10.1186/1746-4358-7-9 22889093
301 Noel-Weiss J, Taljaard M and Kujawa-Myles S. Breastfeeding and lactation research: exploring a tool to measure infant feeding patterns. Int Breastfeed J. 2014;9:5. PMID: 24834106. 10.1186/1746-4358-9-5 24834106
302 Thulier D. A call for clarity in infant breast and bottle-feeding definitions for research. J Obstet Gynecol Neonatal Nurs. 2010;39(6):627–34. PMID: 21044147. 10.1111/j.1552-6909.2010.01197.x 21044147
303 Bruun S, Buhl S, Husby S, . Breastfeeding, Infant Formula, and Introduction to Complementary Foods-Comparing Data Obtained by Questionnaires and Health Visitors’ Reports to Weekly Short Message Service Text Messages. Breastfeed Med. 2017;12(9):554–60. PMID: 28832183. 10.1089/bfm.2017.0054 28832183
304 Bowatte G, Tham R, Allen KJ, . Breastfeeding and childhood acute otitis media: a systematic review and meta-analysis. Acta Paediatr. 2015;104(467):85–95. PMID: 26265016. 10.1111/apa.13151 26265016
305 Su W, Hui Y, Guo Y, . Early life primary prevention against infant bronchial asthma: a 3-year follow-up. International journal of clinical and experimental medicine [serial on the Internet]. 2020 [cited KQ Search - Cochrane; 13(3): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-02147346/full.
306 Shrestha SK, Arora A, Manohar N, . Association of Breastfeeding and Early Childhood Caries: A Systematic Review and Meta-Analysis. Nutrients. 2024;16(9). PMID: 38732602. 10.3390/nu16091355 38732602
307 Bachrach VR, Schwarz E and Bachrach LR. Breastfeeding and the risk of hospitalization for respiratory disease in infancy: a meta-analysis. Arch Pediatr Adolesc Med. 2003;157(3):237–43. PMID: 12622672. 10.1001/archpedi.157.3.237 12622672
308 Zheng M, Cameron AJ, Birken CS, . Early Infant Feeding and BMI Trajectories in the First 5 Years of Life. Obesity (19307381). 2020;28(2):339–46. PMID. 10.1002/oby.22688