# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Brandy Peaker, MD, MPH, and Tina Fan, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; the U.S. Food and Drug Administration, Office of Research on Women’s Health, and the National Institute on Minority Health and Health Disparities for providing federal partner review of the draft report; Whitney Bender, MD, Maya Bunik, MD, MSPH, Ann L. Kellams, MD, IBCLC, and Adam Lewkowitz, MD, MPHS, who provided expert review of the draft report; and Melinda Davies, MAIS, Leslie Perdue, MPH, and Jill Pope, BA, at the Kaiser Permanente Center for Health Research for technical and editorial assistance.