# Chapter 4 Discussion

## Summary of Evidence

We included 90 RCTs that examined the effectiveness of interventions to encourage and support breastfeeding. The results of this review are consistent with our 2016 review of this evidence^2^ and indicate that interventions delivered by professionals and peers and those delivered remotely can increase the proportion of women who continue any breastfeeding or exclusive breastfeeding up to 6 months postpartum. The included RCTs represent women from developed countries, with diversity in age, primiparity, race and ethnicity, and socioeconomic status. Approximately one-third of the trials were conducted in the United States, and most specifically enrolled women of color and those from socioeconomically disadvantaged backgrounds, who historically have lower prevalence of breastfeeding initiation and continuation.

A summary of the evidence, including our strength of evidence ratings for all KQs, is presented in Table 9.

Table 9 Summary of Evidence

KQ | No. of Included Trials; No. of Participants | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
KQ 1: Infant and maternal health outcomes | Infant health outcomes:; k=10; n=6,592; Maternal health outcomes:; k=11; n=5,441 | Mixed results for the effects on infant gastrointestinal outcomes (k=2): one trial (n=182) found greater risk of ≥1 diarrheal episodes over 3 months in usual care vs. intervention groups (RR, 2.15 [95% CI, 1.16 to 3.97]) while the other trial (n=338) found no difference between intervention and control groups at 1 year (22.7% vs. 25.7%). One trial (n=338) found no difference in risk of otitis media (43.6% vs. 54.9%) or the number of healthcare visits for respiratory tract illnesses (76% vs. 83.4%) at 1 year. Eight trials reported lower rates of healthcare visits and hospitalizations among infants in intervention groups at up to 6 months, although differences between groups were not statistically significant.; Nine trials (n=2,334) reported minimal differences between groups in maternal well-being at up to 3 months postpartum. | Infant health outcomes: NA Maternal well-being: Consistent, Precise | Infant health outcomes variably reported.; Most outcomes based on maternal recall. Considerable range in followup from 4 weeks to 1 year. | Infant health outcomes: Insufficient; Maternal well-being: Low for no benefit | Represents data from the United States and abroad; US trials represent predominately; Hispanic and Black low-income individuals.
KQ 2: Breastfeeding outcomes | k=89; n=49,597 | Breastfeeding support interventions were associated with a higher likelihood of exclusive breastfeeding initiation and of any and exclusive breastfeeding up to and at 6 months. There was no apparent effect on any breastfeeding initiation, but rates of breastfeeding initiation were relatively high in both intervention and control groups. Few studies reported rates of breastfeeding at 1 year.; Pooled RR (95% CI) for each outcome were:; Any breastfeeding:; - Initiation: 1.01 (1.00, 1.02), k=37, n=15,006; - <3 mo: 1.06 (1.03, 1.08), k=47, n=15,663; - 3 to <6 mo: 1.09 (1.04, 1.12), k=40, n=17,580; - 6 mo: 1.13 (1.05, 1.22), k=37, n=13,579; - 12 mo: 1.04 (0.91, 1.18), k=8, n=4,607; Exclusive breastfeeding:; - Initiation: 1.16 (1.05, 1.29), k=27, n=10,622; - <3 mo: 1.21 (1.14, 1.28), k=51, n=17,580; - 3 to <6 mo: 1.31 (1.17, 1.46), k=40, n=11,032; - 6 mo: 1.46 (1.20, 1.78), k=37, n=14,398 | Consistent, Precise | Clinical variation in samples.; Lack of detail regarding measurement of breastfeeding, including recall period and definition of exclusivity.; Sparse reporting of breastfeeding at 12 months. | Moderate for benefit | US trials (k=33, 37% of trials) represent predominantly Hispanic and Black low-income women. Non-US trials have unclear applicability to US settings given differences in usual care and underlying social and cultural differences.
KQ 3: Harms | k=28; n=15,011 | Six trials reported “no adverse events” related to the intervention. One trial reported greater feelings of anxiety, decreased confidence, or concerns of confidentiality among intervention mothers and not among control group mothers. Twenty-two trials reported the incidence of breastfeeding problems, generally finding that women in the intervention groups experienced fewer problems or difficulties than women in the usual care control groups. | Consistent, Precise | Only seven trials reported harms and details about specific harms were lacking.; Problems or difficulties related to breastfeeding could be a harm (due to increased breastfeeding) or could be improved because of the intervention. | Low for no harm | Unclear applicability given proportion of trials reporting harms.

Abbreviations: BMI = body mass index; CI = confidence interval; K = number of studies; KQ = Key Question; mo = months; N = number of participants; NA = not applicable; US = United States.

### Infant and Maternal Health Outcomes

The effects of the interventions on infant and maternal health outcomes were minimally reported. Few studies overall reported infant health outcomes from birth to up to 12 months, and measures of gastrointestinal outcomes, otitis media, and respiratory tract infections were only reported in one to two relatively small- to medium-sized trials each. Eight trials reported general measures of infant illnesses and healthcare utilization at up to 6 months and found trends of lower rates of healthcare visits and hospital admissions among infants in the intervention groups compared with usual care groups, although these differences were not statistically significantly different in any of the trials. In nine trials that reported outcomes related to maternal well-being, minimal differences were seen between intervention versus control group women in symptoms of anxiety, depression, or well-being at up to 6 months postpartum.

Despite this limited evidence on the direct effect on health outcomes from the included trials, observational evidence (as described in Chapter 1) supports the link between ever breastfeeding and the duration of any or exclusive breastfeeding and positive infant and maternal health outcomes.

### Breastfeeding Outcomes

This review showed moderate-certainty evidence that interventions to support breastfeeding increased the likelihood of breastfeeding and exclusively breastfeeding up to 3 months, 3 to 6 months, and at 6 months compared with usual care. Data on the effects of breastfeeding support interventions on the prevalence of breastfeeding at 1 year were limited. There was no apparent influence of interventions on initiating any breastfeeding compared with usual care; however, a beneficial association was seen in increasing exclusive breastfeeding initiation.

The size of the effects varied in their magnitude and precision in different trials, and the average treatment effects may not be applicable across different populations and settings. The pooled estimates suggested an increase in any breastfeeding from 6 to 13 percent and an increase in exclusive breastfeeding from 16 to 46 percent up to 6 months. The average treatment effect for exclusive breastfeeding at 6 months suggested that interventions can increase the likelihood of exclusive breastfeeding by an average of 46 percent compared with usual care (RR, 1.46 [95% CI, 1.20 to 1.78]). Effect estimates were larger for exclusive breastfeeding than for any breastfeeding at all time points—a finding that cannot be easily explained by the included evidence. One possible explanation is that interventions that go above and beyond usual care may emphasize the importance of exclusive breastfeeding to a greater degree than emphasizing breastfeeding in general. This may be particularly true for samples of women who were intending to breastfeed and motivated to begin with, as was evident in the included studies.

We calculated the NNT for benefit based on a range of “baseline” breastfeeding prevalence as seen in the included control groups and the pooled risk ratios (Appendix E Table 4). The NNTs for any and exclusive breastfeeding at each time point generally indicated that fewer than 25 women would need to be treated to get one more person breastfeeding at up to 6 months and fewer than 40 women treated to maintain exclusive breastfeeding at up to 6 months. Among groups of women with higher rates of breastfeeding, the NNT to get one more person breastfeeding is lower. For example, among populations of women where approximately 50 percent of them breastfed at 6 months, the NNT is 15. On the other hand, in situations where there are fewer women exclusively breastfeeding on average (e.g., 5% exclusively breastfeeding at 6 months), approximately 43 women would need to receive an intervention to see one more person exclusively breastfeeding at this time point.

The relatively modest effects seen within individual trials may be a result of the breastfeeding support provided as part of standard or usual care within many of these countries and specific clinical settings, and the magnitude of effect should be interpreted as an incremental benefit above usual care. Most studies indicated that there was a good level of breastfeeding support within the birthing facility at or around the time of delivery from hospital staff, including the provision of lactation care providers, but failed to fully describe the minimal support for breastfeeding during the prenatal and postpartum time periods.

Meta-regression and tests for subgroup differences revealed possible patterns of larger effects for studies taking place in the different countries, those among women who were not intending to breastfeed, and interventions that spanned multiple time periods versus their counterparts; but these findings were not consistent across all timepoints or outcomes and thus need further study. It is likely that there are other factors that may confound these relationships and explain differences in effectiveness. Interventions provided by both professionals and peers were associated with greater prevalence of any and exclusive breastfeeding compared with usual care. Furthermore, there was no apparent difference in effectiveness between studies that were delivered primarily in-person versus those delivered remotely.

### Harms

There was no evidence of increased harm due to additional breastfeeding support. Six of seven studies that recorded potential harm of the intervention reported no harms among participants. One intervention that provided peer support included reports of increased anxiety, feelings of inadequacy, and concerns regarding the family’s confidentiality. Although the goals of these interventions focused on helping and empowering women to both initiate and continue breastfeeding, it is important that interventionists respect a family’s individual decisions and remain flexible in supporting new mothers and their feeding choices.

We also examined common problems related to the act of breastfeeding itself that may be important determinants of continued breastfeeding, including cases of mastitis or sore nipples. In general, women in the intervention groups reported experiencing fewer breastfeeding problems than women in the control groups at all measured time points. Interventions to support breastfeeding have the potential to increase these problems (through the increased prevalence of breastfeeding among the population) or to decrease these issues (through active management and suggestions for prevention). Given that these breastfeeding-related problems are often the impetus for stopping breastfeeding,^59^ part of the goal of any intervention should be to help breastfeeding mothers actively prevent and manage these common issues.

## Applicability to U.S. Healthcare

Collectively, the trials included samples of individuals representative of the population of the United States; most, however, included participants who intended to breastfeed. The average age of participants ranged from 16 to 33 years and both primiparous and multiparous persons were represented. Over a third of the included evidence was from trials in the United States. The remaining studies took place in European or Asian countries, Australia, or Canada, where we presume the standard of care for breastfeeding, and general infant and maternal health, to be different from that of the United States. Trials outside of the United States rarely reported the race and ethnicity and socioeconomic status of the samples, although some explicitly described representation from “low-income” and “culturally diverse samples.” Among the trials taking place in the United States, almost all included mostly Hispanic or Latina or Black women, and many were either limited to or predominantly included participants within lower income categories. Among the studies in the United States, five explicitly said that the intervention was offered in a BFHI-accredited facility;^126,^ ^129,^ ^140,^ ^172,^ ^174^ the other studies reported varying levels of breastfeeding support within usual care.

We identified no single optimal or representative intervention but rather found that a wide range of approaches may improve rates of breastfeeding and are likely applicable to infant and maternal care in the United States. The interventions offered were diverse. Some consisted of only group prenatal education sessions. Some only included in-person support at and around the time of birth. Some consisted of telephone support alone. Some utilized test and app-based contact. Some included intense home visits. And some included multiple one-on-one sessions spanning the prenatal and postpartum periods. A summary of information regarding the details of the types of interventions represented in this review is provided in Appendix F to guide those wishing to implement breastfeeding support interventions.

## Programs to Help Facilitate Access to and Utilization of Breastfeeding Support Interventions, Including Evidence on Healthcare System-Level Interventions and Hospital Policies (Contextual Questions 3 and 4)

Though our review was limited to interventions implemented at an individual level, there are several healthcare- and policy-level programs in the United States in place to help facilitate access to and equitable support.

### Baby-Friendly Hospital Initiative

One of the largest breastfeeding support programs implemented in the broader healthcare setting is the BFHI. The BFHI was launched by the WHO/UNICEF in 1991 as a global program to encourage the broad implementation of the Ten Steps to Successful Breastfeeding (Ten Steps) and the International Code of Marketing Breast-milk substitutes.^60^ Broadly, the BFHI program supports hospitals in providing mothers the information, confidence, and skills necessary to successfully initiate and continue breastfeeding their infants and designates special recognition to hospitals that are part of the program. In cases where it is medically necessary to offer commercial formula or the mother has made an informed decision to not breastfeed or provide breast milk, BFHI facilities provide mothers with information on the safe preparation and feeding of formula. However, the BFHI program never explicitly promotes formula feeding or non-breast milk options as an alternative to breastfeeding.^60^ Hospitals in compliance with BFHI policies can earn the Baby-Friendly^®^ designation, which carries a 5-year term before a renewal process must be initiated.^247^ The Ten Steps are the framework underlying the BFHI program and are the practices which hospitals must follow to receive Baby-Friendly^®^ status; they were developed by an international team of breastfeeding and infant care experts, are guided by evidence-based practices, and were most recently updated in 2018.^61^ The Ten Steps are outlined in Table 3.

The Ten Steps are endorsed and promoted by major maternal and child health organizations in the United States, including the AAFP, the ACOG, the Centers for Disease Control and Prevention (CDC), WIC, and the U.S. Surgeon General. As of May 2023, there are currently 603 healthcare facilities in the United States with BFHI Baby-Friendly^®^ designation, and nearly 27 percent of annual births occur in these facilities.^248^ BFHI designation has increased from 5 percent of all eligible healthcare facilities in the United States in 2008 to currently more than 25 percent as of 2022. During this period, as the percentage of BFHI facilities increased, so has the percentage of babies ever breastfed (74% to 82%).^60^ Despite the observed increase in breastfeeding rates corresponding to an increase in number of BFHI healthcare centers, there is mixed evidence on whether the BFHI program is associated with better breastfeeding outcomes and how long those outcomes can be sustained, especially in highly developed countries that have additional avenues of breastfeeding support such as the United States.

The Promotion of Breastfeeding Intervention Trial (PROBIT), the largest study ever conducted on the effectiveness of breastfeeding support, evaluated a support intervention modeled on WHO/UNICEF’s Ten Steps in Belarus.^249^ This study was not included in our review because of its limited applicability to U.S.-based healthcare given the country of origin. At the inception of this trial (1996–1997), Belarus was chosen rather than a North American or Western European country because maternity practices there reflected those in North America and Western Europe 40 to 50 years ago and therefore would provide greater potential contrast between intervention and control conditions. Nonetheless, it is an important study that has contributed data on the effectiveness of an individual and system-level intervention on rates of breastfeeding and infant and maternal health outcomes. In the early 2000s, PROBIT enrolled over 17,000 pregnant women, randomizing them to receive breastfeeding promotion/support or usual care; women and their infants were followed for 20 years and over 50 subsequent articles reporting long-term outcomes (e.g., healthcare utilization, cognitive outcomes, health outcomes such as BMI, diabetes) have been published.^249^ A 2012 review summarized all published PROBIT articles reporting breastfeeding outcomes, noting that women who received the support intervention had higher rates of exclusive breastfeeding and longer duration of breastfeeding compared with women who received usual care.^250^

Systematic reviews assessing the efficacy of support programs at currently accredited BFHI hospitals—and in settings more applicable to the United States—however, reveal mixed findings on whether the program is associated with long-term increases in rates of breastfeeding and improvement in other health outcomes.^251–255^ Additionally, an analysis of CDC Breastfeeding Report Card data found that Baby-Friendly^®^ facilities were not significantly associated with any post-discharge breastfeeding outcomes (any breastfeeding at 6 and 12 months, exclusive breastfeeding through 3 and 6 months).^256^ Other reviews have found that the initially observed increase in breastfeeding rates associated with BFHI programs are not sustained past breastfeeding initiation.^254,^ ^255^

Although there is mixed evidence on whether the BFHI program is effective at improving overall breastfeeding rates, it has been suggested that specific elements of the BFHI approach may be effective and worth continuing to implement in clinical practice. A 2022 umbrella review evaluated the effectiveness of systems-level breastfeeding programs on increasing rates of breastfeeding and noted that several specific factors of the BFHI program, such as rooming-in and prolonged skin-to-skin contact, have a strong and consistent evidence base supporting their utility to increase breastfeeding and improve infant health outcomes.^251^ A separate review evaluated the third step of the program (providing prenatal education) and found that these programs show benefit when prenatal education contains informational material and interpersonal support, but noted that lack of standardization in BFHI-sponsored interventions makes it difficult to draw conclusions about the efficacy of the program overall.^252^ This lack of standard support services and curricula within the BFHI program has been critiqued. Some have argued that because WHO/UNICEF allows each BFHI facility to create their own strategy to implement the Ten Steps, and does not require a certain staffing ratio or specific trainings, this has led to issues such as understaffing or lack of staff training to ensure that all initiatives can be successfully implemented.^257^ Currently, pediatric residents receive minimal breastfeeding-specific training, and there is a lack of robust evidence to support offering provider knowledge interventions to improve uptake and delivery of breastfeeding counseling programs.^258^

Additional concerns regarding the BFHI as a whole also exist. There is some criticism that the BFHI program is too rigid and may promote unrealistic breastfeeding expectations for mothers.^253,^ ^255^ Many argue that flexibility and supporting new mothers and their feeding choices—whether breastfeeding, formula, or mixed feedings—is ultimately more important than ensuring exclusive breastfeeding is achieved at the expense of maternal and infant wellbeing.^257,^ ^259^ One review conducted a synthesis of qualitative studies reporting mothers’ experiences delivering at BFHI institutions, and found that women reported both positive and negative experiences, with the latter being more common.^253^ For instance, one study conducted in mothers who delivered via cesarean section at a BFHI-certified institution expressed alarm when they were expected to immediately start breastfeeding without any regard to postsurgical recovery.^260^ Additionally, other studies found that mothers have reported feeling undermined and discouraged when providers at BFHI facilities use judgmental language surrounding feeding practices (e.g., a nurse saying that using a bottle to feed expressed milk will “confuse” the infant),^261^ and feeling guilty when they encounter challenges in breastfeeding, especially when it is promoted as “easy” and “natural.”^262^ In this same study, participants reported feeling that healthcare providers were withholding information on formula feeding, and felt the need to discuss formula feeding covertly and even hide bottles to avoid being criticized for not breastfeeding.^262^ Some individuals reported that healthcare providers lacked both communication skills and adequate patient time, leaving them feeling “really bad” about asking for help and feeling their need for breastfeeding support is a burden.^263^ Similarly, a separate study’s participants reported that BFHI information and feeding guidance was communicated in an impersonal manner and was not tailored to each woman’s and family’s needs.^264^

### Supplemental Nutrition Program for Women, Infants, and Children

Another nationwide, system-level resource to assist supporting breastfeeding mothers and infants is the U.S. Department of Agriculture’s Food and Nutrition Service’s Supplemental Nutrition Program for Women, Infants, and Children, commonly known as WIC.^265^ The WIC program aims to safeguard the health of low-income women, infants, and children up to age 5 years who are at nutrition risk by providing nutritious foods to supplement diets, information on healthy eating, and referrals to healthcare;^266^ breastfeeding support is also a key component of WIC services for pregnant mothers and mothers in the perinatal and postnatal periods. WIC was founded in 1972 as a pilot food supplementation program to improve the health of lower-income pregnant persons and their children.^267^ Historically, WIC has sought to support breastfeeding in a variety of ways, primarily including tailored supplemental nutrition programs. However, within the past few decades, there have been several changes to the WIC program to provide more comprehensive support to program recipients—especially breastfeeding mothers—including better alignment with dietary guidelines and provision of culturally sensitive foods. In 1992, WIC added a food package specifically tailored to breastfeeding women, and in 2009, the program revised its food packaging in an effort to incentivize breastfeeding by reducing some foods, adding others, and allowing for a cash voucher to purchase fresh produce.^268^ In addition to food package support, currently, WIC offers breastfeeding support via peer counselors, telephone hotlines, and access to professional lactation consultants.^265^

The general eligibility requirements to receive WIC benefits include being a woman breastfeeding and/or caring for an infant(s) up to age 1 year or a child(ren) up to age 5 years, residing in the state of the WIC program to which they apply, having an income at or below 100 to 185 percent of the federal poverty guideline, and having a professionally determined nutrition risk.^269^ In 2020, the WIC eligibility rate among pregnant women was 40 percent, with nearly 46 percent of eligible women receiving benefits. Among breastfeeding women, about 45 percent were eligible for WIC, and 60 percent of those women received WIC services.^270^ WIC serves a diverse population; in 2020, 4.8 million infants and children eligible for WIC were White, just over 4 million were Hispanic, 2.6 million were Black, and just over 1 million were of other races or multiple races. Hispanic infants and children had the highest coverage rate in 2020 (64%); the coverage rate was 56 percent for infants and children of other race and ethnicities or multiple races and ethnicities, 50 percent for Black infants and children, and 38 percent for White infants and children.^270^ WIC serves a critical need in increasing access to breastfeeding support programs to historically underserved populations. Women with lower income (a WIC eligibility requirement) are less likely to breastfeed and may face barriers in accessing adequate healthcare and breastfeeding support services.^271^

Several studies, including studies in this review,^146,^ ^157,^ ^193^ have examined the association between WIC participation and breastfeeding rates; however, strength of evidence and duration of effect are mixed.^272–275^ A 2022 systematic review found moderate strength of evidence that maternal WIC participation is likely to be associated with no difference in breastfeeding initiation rates, and found that evidence is insufficient to determine whether maternal or child WIC participation is associated with longer duration of breastfeeding or exclusive breastfeeding.^276^ Regarding other outcomes, the review found that WIC participation is likely to be associated with reductions in infant mortality, increased well-child visits, and receipt of scheduled immunizations during the first year of life, but evidence is insufficient to determine whether participation affects other child health outcomes such as morbidity and mortality.^276^ Additionally, a secondary analysis (n=1,235) of the WIC Infant and Toddler Feeding Practices Study-2^277^ found that the association between WIC participation and breastfeeding success is dependent on individual-level programming at each WIC location (e.g., access to IBCLCs, number of home visits allowed, varying formula provision policies).^273^

As detailed above, in 2009, there were revisions to the WIC food packaging requirements including modifications to include fresh produce vouchers, whole grains, reduced-fat milk, milk substitutes (cheese, yogurt, and tofu), and less juice and milk.^268^ Whether these revisions have been successful in their goal to improve breastfeeding rates among WIC participants has been contested. A 2023 review of five studies including over 500,000 women-infant pairs found low strength of evidence that the changes to food packages were associated with greater breastfeeding exclusivity,^278^ and a single study of 4,308 participants found that the disparities in prevalence of ever breastfeeding in WIC-eligible compared with non-participants have been eliminated since the 2009 revisions.^279^ However, a quasi-experimental study of 1,114 participants found no significant differences in breastfeeding rates pre- and post-change.^280^

### Nurse Family Partnership

Another public program that may provide breastfeeding support, targeted towards first-time mothers, is the Nurse Family Partnership (NFP). The NFP is a free, nationwide program (currently in 40 states) funded by Medicare and individual states’ health departments that aims to “keep children healthy and safe and improve the lives of moms and babies,” including providing comprehensive breastfeeding support and advice both pre- and post-natally.^281^ The NFP was established as a national program in 1996 and has since provided support to over 385,000 families. To qualify for services, mothers must be nulliparous, currently pregnant and at 28 weeks’ gestation or less, and must be at or below 235 percent of the federal poverty level; women who receive WIC or Medical Assistance are automatically eligible for the program.^282^ Some states do offer NFP services to primiparous or multiparous mothers, provided they meet other eligibility requirements.^281^

Though the NFP is a broad maternal and child health support program that focuses on general health education and providing resources for unmet social needs, there can be an emphasis on infant and child nutrition—which may include breastfeeding. Additionally, by providing enhanced support that may mitigate some of the psychosocial stressors faced by program enrollees, the NFP may allow mothers to choose breastfeeding or to attempt breastfeeding when they otherwise may not be able to attempt or achieve that goal without the additional support offered by the NFP. Visits begin in early pregnancy and continue through the child’s second birthday. Nurses and mothers determine the frequency of visits, and support persons (e.g., child’s father, family members, friends) are also encouraged to participate. NFP nurses are also able to assist mothers and families with referrals to social services, community resources, and generally help create a safe, loving home environment for baby and family.^281^ Information on breastfeeding and referral to other resources (e.g., La Leche League) is provided when needed or desired, but notably, nurses do not receive additional lactation training provided by the NFP, and no specific breastfeeding materials are used during the home visits.^283^

There is scant contemporary peer-reviewed literature on the efficacy of the NFP program on improving breastfeeding rates, but an older systematic review including six trials that evaluated the NFP program reports that, in general, participation in the NFP program increases breastfeeding attempts by about 10 percent.^284^ As noted in the previous section, breastfeeding rates for women enrolled in WIC are lower compared with women not enrolled in the program, even though a primary aim of WIC is providing ongoing nutrition and breastfeeding support. To assess whether women enrolled in the NFP also have paradoxically lower breastfeeding rates than women not receiving tailored support, a cohort study analyzed the breastfeeding rates of 3,570 mothers and infants enrolled in the NFP between 2000 and 2005, comparing differences in breastfeeding rates among mothers enrolled in both the NFP and WIC programs or NFP alone.^283^ Rates of any breastfeeding were significantly higher at 6 and 12 months among mothers only enrolled in the NFP (29.5% and 16.2%, respectively) compared with mothers enrolled in both NFP and WIC (19.2% and 9.8%, respectively). However, when included in multivariate analyses, enrollment in WIC was not a significant predictor of breastfeeding at 6 months. Though it remains unclear why participation in WIC is associated with lower rates of breastfeeding, there is a positive relationship between NFP enrollment and continuing breastfeeding.

### Other National Programs or Policies

In addition to the BFHI and WIC and NFP programs, there are several legal protections regarding the promotion of breastfeeding at the national level. The Affordable Care Act (ACA) mandates that healthcare plans (with few exceptions) provide breastfeeding support, counseling, and equipment for the duration of breastfeeding, including in the prenatal and postnatal periods; plans must also fully cover the cost of a breast pump.^285^ In 2023, the Providing Urgent Maternal Protections (PUMP) for Nursing Mothers Act^286^ was implemented, requiring workplaces to provide, among other things, 1) a reasonable break time for an employee to express breast milk each time they need to express for a 2-year period, and 2) a place, other than a bathroom, that is shielded from view and free from intrusion from coworkers and the public, which may be used by the employee to express breast milk. The passing of the PUMP Act expands breastfeeding protections to nearly 9 million women who were not previously covered under the ACA and also includes enforcement mechanisms against noncompliant employers.^287^

## Comparison With Other Systematic Reviews

The results of our current review are consistent with the findings from a 2022 Cochrane review (Gavine et al.),^288^ suggesting that interventions to support breastfeeding increased the relative likelihood of sustained breastfeeding (including exclusive breastfeeding) at up to 6 months. In this review, at 6 months, interventions providing focused breastfeeding support reduced the likelihood of discontinuing any breastfeeding for women in both developed and developing countries receiving the intervention compared with women receiving no support or usual care (RR, 0.93 [95% CI, 0.89 to 0.97]), with similar effects observed for the outcome of exclusive breastfeeding (RR, 0.90 [95% CI, 0.88 to 0.93]). Weaker but still significant effects were reported in the Cochrane review for reduced likelihood of discontinuing exclusive breastfeeding at 4 to 6 weeks (RR, 0.83 [95% CI, 0.76 to 0.90]) as well as any breastfeeding at the same timepoint (RR, 0.88 [95% CI, 0.79 to 0.97]). The Cochrane review concluded that there is less robust evidence on differential effects of breastfeeding only versus “breastfeeding plus” interventions, which mirrors our conclusions in the current review.

Both our current review and the Cochrane review found no consistent differential effects of intervention delivery, length, mode, or interventionist across outcomes or timepoints. Unlike the Cochrane analyses, the current review only included interventions conducted in very high development countries. Furthermore, the Cochrane review included both RCTs and “quasi-RCTs,” whereas our review only included RCTs. Authors of the Cochrane review cited similar challenges to this literature base, including the high risk of bias of the included studies, the lack of standardization of breastfeeding outcomes and incomplete reporting of study characteristics, and the need for further research including outcomes on maternal mental health and other components of interventions that may be effective in providing breastfeeding support and support for general maternal and infant well-being.

## Limitations of Our Approach

There are limitations to our review approach that should be noted. Given the audience for this review—the U.S. Preventive Services Task Force—we limited our inclusion to interventions that were conducted in or feasible for primary care. We did not include studies of interventions that focused on strategies that extend beyond the purview of a primary care clinician or practice including hospital or workplace policies or strategies. We included trials of interventions that take place in the community, including those offered by WIC programs, as a source of support that primary care clinicians could refer their patients to.

We restricted our review to RCTs that we rated as fair or good quality to minimize the potential for confounding and other sources of bias in the results. As such, we excluded many trials that may have addressed additional populations, settings, and interventions of interest. One study excluded for poor quality is worth noting given its novel approach and audience. In an Australian trial by Scott et al., expecting couples were recruited from prenatal classes and randomized to one of four arms: a face-to-face father-focused prenatal class facilitated by a peer counselor, a breastfeeding smartphone app (“Milk Man”) designed specifically for fathers, a combination of these two interventions, or usual prenatal breastfeeding classes. The trial suffered from very high attrition with 59 percent and 49 percent of participants having complete data at 6 and 26 weeks, respectively. Results from both completers-only and imputation for missing data analyses were presented. While each intervention was found to be feasible, useful, and acceptable to fathers in terms of the intent, content, and delivery, there was no impact of the face-to-face, app, or combination interventions on maternal breastfeeding.^289^ Further study of these types of interventions, particularly smartphone apps, among support persons, may be warranted.

Additionally, we chose to pool data from studies representing a variety of interventions, including those that focused only on breastfeeding support and those that included additional content beyond breastfeeding. Furthermore, in order to pool data from multiple studies, we chose to use the raw event rates and total number of participants randomized to calculate within-study risk ratios to combine. Therefore, our analyses did not control for potential confounding factors such as socioeconomic status, employment status, education level, parity, or previous breastfeeding experience. We compared our crude relative estimates with any study-reported unadjusted and adjusted estimates and besides a few exceptions,^130–132,^ ^189^ no differences were seen. Additionally, we did not include other proximal measures such as breastfeeding self-efficacy and early postpartum bonding that may be important outcomes of individual trials.

Finally, we did not systematically review the evidence on the relationship between breastfeeding and short- and long-term child or maternal health outcomes. Thus, we did not complete the entire chain of evidence. We instead focused only on the direct evidence related to the impact of intervention on breastfeeding and health outcomes. The evidence on the associations between breastfeeding and maternal health outcomes is well documented^53^ and an updated review on the association between breastfeeding and infant and child health outcomes is underway.^28^ We informally reviewed recent evidence from existing systematic reviews as a CQ; however, a systematic review might have revealed more data than we found.

## Limitations of the Literature and Future Research Needs

Despite a relatively large number of included trials that evaluated the effectiveness of interventions to increase breastfeeding, there are limitations in the evidence and broader literature that point to important research needs.

First, as demonstrated in this review, few RCTs included measures of infant or maternal health outcomes, including potential harms associated with interventions. Although there is a robust evidence base of observational studies showing that ever breastfeeding and breastfeeding for longer durations is associated with favorable outcomes for children and mothers (Table 2), investigators should be encouraged to include measures of such outcomes in their trials. For infants, this includes acute outcomes such as cases of otitis media, gastrointestinal infection, and lower respiratory illness; the development of asthma and dental caries; and the incidence of developmental and metabolic conditions. Data that directly link differences in breastfeeding (that are related to an intervention) to differences in these outcomes would provide further evidence of the importance of counseling for breastfeeding. We acknowledge, however, that such studies would require considerably larger sample sizes, longer length of followup (ideally, greater than 1 year), and mechanisms for systematically collecting data on such outcomes (through direct assessment or using reliable health record data).

Furthermore, although there were more trials that reported indicators of maternal well-being in this update compared with previous reports, there is still a striking lack of consideration of this as an outcome. Given that adverse maternal mental health has been show to potentially have an impact on breastfeeding initiation, duration, and exclusivity,^290,^ ^291^ breastfeeding support also needs to consider individuals’ emotional well-being and the impact that interventions may have positively or negatively on these measures. We encourage authors to routinely include measures such as the EPDS or the Centre for Epidemiologic Studies Depression Scale (CES-D) or other standardized measures of maternal and parental well-being to examine the influence that specialized breastfeeding interventions that go above and beyond usual care may have on these measures.

Second, although there was no evidence to suggest harm from the interventions, many studies did not report on adverse events, and this is something that should be reported in any future trial. Although we framed the title of this review and the included interventions as interventions to “support” breastfeeding, it is not clear to what extent the participants and their families felt supported in their feeding decisions and approaches, regardless of their intention and motivation to breastfeed or their ability to successfully maintain breastfeeding. At a minimum, authors of these trials should monitor and report participants’ impressions of the support they were given and any differences in reported negative effects. More routine collection of measures of parental well-being and stress would also help elucidate potential harm.

Third, the reporting of the included interventions often was not comprehensive—lacking, for example, in terms of the precise aims and messages (e.g., focus on exclusive breastfeeding, focus on extending the duration of any breastfeeding, help with breastfeeding when transitioning back to work), details on the timing of the intervention sessions and support, details on the training and qualifications of the interventionists, and adherence to the intervention protocol. Furthermore, there was extremely limited detail about the standard care that was offered to both intervention and control participants, especially as it related specifically to breastfeeding support. The lack of this detail makes it very difficult to understand whether the relatively small to modest effects that were seen in individual trials was because of a lack of robust effects of the interventions or because of greater support provided by standard care. To facilitate better implementation, future studies should describe in detail the characteristics of the intervention, the setting, standard of care (including BFHI accreditation and routine lactation support), and the background breastfeeding rates in the population studied.

Fourth, few included interventions appeared to extend support to families beyond 3 months (Figure 4) as the prevalence of breastfeeding continues to decline. Among infants born in 2021 in the United States, most (84.1%) started out receiving some breastmilk and over three-quarters (80.8%) were still receiving any breast milk at 1 month.^5^ This is consistent with data from our review where the median prevalence of breastfeeding initiation among control group participants in U.S.-based studies was 85 percent. Many families, however, do not breastfeed for as long as they intend to and there is a steady decline in any and exclusive breastfeeding from month-to-month (Figure 1) that indicates that families may need stronger support systems beyond just the first few weeks or months after birth.

Breastfeeding support is especially important for individuals who are returning to work and wanting to continue breastfeeding. A lack of paid maternity leave and supportive workplace and childcare policies for breastfeeding likely contribute to declines in rates of breastfeeding and continued disparities. Beyond the need for greater efforts in these areas, future research applicable to this review should explore how to best support individuals to continue breastfeeding at these critical junctures where support needs are likely to be different. Future interventions should consider preemptively focusing on preparing for return to work (e.g., how far in advance should one consider pumping and storing breast milk, how much breast milk might one need to provide during childcare) and continuing that support as time passes when motivation to continue breastfeeding might decrease and barriers may increase. Additionally, studies should explicitly state what proportion of participants are employed and plan to return to work and examine to what extent these variables influence intervention effectiveness. Furthermore, future studies evaluating the effectiveness of digital breastfeeding support interventions, especially those that provide longer term access and contact to support, are warranted.

Fifth, related to the issues above, there was a striking lack of attention (or reporting) on interventions that focus on or incorporate content about breastfeeding that extends beyond direct-to-breast feeding methods, including expressing and bottle-feeding infants and the use of donor breast milk. Recent data is lacking, but in the 2005–2007 Infant Feeding Practices Study II, 85 percent of breastfeeding mothers of infants ages 1.5 to 4.5 months had successfully expressed milk at some time since their infant was born.^292^ Almost 6 percent of these women never fed their infants at the breast and fed them expressed milk exclusively. There are many reasons that individuals express their milk, including the ability to have someone else feed the baby and to accommodate continued breastfeeding upon return to work and the use of childcare. Milk expression and storing, however, comes with its own challenges and barriers that may require additional support beyond the support provided within interventions such as those evaluated in this review.^293^ At a minimum, new studies testing the effectiveness of breastfeeding support interventions should describe in detail to what extent expressing and storing breast milk is part of the intervention content.

Similarly, there was no included evidence on interventions that discuss or promote the use of pasteurized donor milk to meet infants’ nutritional needs. This is likely related to our exclusion of studies limited to high-risk infants for whom pasteurized donor human milk is seen as the preferred substitute when there is an inadequate supply of the mother’s own milk.^61,^ ^294^ Nonetheless, future studies should acknowledge the extent to which the use of pasteurized donor milk was discussed or included in messages about breastfeeding. And, given the concern that the introduction of donor human milk may lead to a decrease in breastfeeding,^295^ outcome measures should distinguish between the mode of feeding and source of breast milk, as further elucidated below.

Sixth, despite several calls to standardize breastfeeding definitions and indicators for both surveillance and program evaluation,^23,^ ^293,^ ^296–302^ there was no uniform reporting of breastfeeding outcomes across the included studies regarding definitions of breastfeeding and timing of assessments. Most of the studies followed the WHO definition for exclusive breastfeeding,^20^ but others used less robust definitions or did not report what counted as exclusive breastfeeding. Few studies specified whether recall was based on the previous 24 hours (i.e., exclusive breastfeeding for the past 24 hours) or having been exclusively breastfeed since birth. In addition, there was a lack of clarity concerning the boundary point for many of the prevalence time points. That is, it was unclear if exclusive breastfeeding reported for 6 months was exclusive breastfeeding at 6 months or exclusive breastfeeding to 6 months, which is technically the recommendation (the introduction of something other than breast milk at or after 6 months among otherwise exclusively breastfed infants). We pooled the results for exclusive breastfeeding at 6 months as was reported in the individual trials but suspect this technically means the infant was exclusively breastfed up to 6 months (i.e., did not receive any milk substitutes but may have received solids). Only five included trials included a measure of breastfeeding “intensity” based on the proportion of feedings that were breast milk; future research should consider this more nuanced breastfeeding indicator to further distinguish the effects of breastfeeding interventions. Also, very few of the studies noted whether their definition of breastfeeding included feeding the infant expressed breast milk in addition to direct-to-breast breastfeeding. We encourage investigators of future studies to note the specific instrument that was used to capture breastfeeding behavior; describe verbatim the questions that were posed to mothers; and note the specific definitions (in terms of content and feeding method), recall period, and time point related to the measure.

To increase precision in outcomes and increase response rates, investigators may want to consider short infant feeding SMS text surveys. As has been shown,^303^ frequent app-based breastfeeding data collected from mothers have been validated against other more labor-intensive methods such as self-administered questionnaires and health visitor reports and has been shown to reduce participant burden and provide reliable, more complete data. Future studies should consider collecting minimal data related to feeding outcomes of interest via frequent but short surveys administered from within apps or via SMS text. These methods could also allow for questions regarding the infant and maternal health and well-being outcomes such as rates of doctor’s visits and infant illness, breastfeeding-related challenges and problems, and indicators of stress and well-being.

Finally, this review provides clear evidence that interventions that support women in starting and continuing to breastfeed above and beyond what is typically provided in usual care can improve the proportion of those who breastfeed and the duration of breastfeeding. The key research question in the future may be to identify how such support can be provided consistently, for all persons, of all backgrounds and in all locations. Research efforts may need to focus less on effectiveness and more on implementation and quality improvement studies and approaches. A greater emphasis should be placed on approaches to improve access to services, particularly for those living in remote areas or with transportation and logistical challenges for meeting in-person. The COVID 19 pandemic has increased the skills of both patients and providers in using digital and other remote technologies to receive and deliver care and could enhance access to future interventions. In addition, as reviewed in Chapter 1, there are numerous complex factors that contribute to disparities in rates of breastfeeding. It is important that future efforts to encourage and support breastfeeding take these differences, and the underlying factors that influence them, into account.

We identified nine ongoing studies in the United States that address some of these limitations and may be relevant for future updates of this review (Appendix G). Most of these studies focused on novel interventions including the use of text messaging and smartphone applications, a video and website specifically focused on how to hand-express breast milk, integrating peer counseling into postpartum care, and a postpartum patient navigation program to help address the social needs of families to improve infant health and breastfeeding outcomes.

## Conclusions

The updated evidence confirms that breastfeeding support and education that is provided during pregnancy and postpartum by professionals and peers can increase the prevalence of any and exclusive breastfeeding up to and at 6 months. Trials that take place in the United States represent a diverse population of women for whom rates of breastfeeding are historically low. Future efforts should focus on how to best provide this support consistently for individuals of all backgrounds who are making feeding decisions for their infant.