# Chapter 3 Results

We screened 3,720 abstracts and reviewed 290 full-text articles for inclusion across Key Questions (Appendix B). Overall, we included 90 trials^122–211^ (125 publications total^212–246^) with over 49,000 mother-infant pairs being represented. All studies reported the included samples as either “women” or “mothers”; therefore, our results are reported similarly. Two independent studies were reported within one publication: the Best Infant Nutrition for Good Outcomes (BINGO) study is referred to as Bonuck, 2014a^131^ and the Provider Approaches to Improved Rates of Infant Nutrition & Growth Study (PAIRINGS) is referred to as Bonuck, 2014b.^132^ All but one of the included studies addressed KQ 2; 19 of these studies addressed KQ 1 and 28 addressed KQ 3. Forty-three trials were carried forward from the previous review and 47 trials were newly identified in this update.

The lists of included and excluded studies (with reasons for exclusion) are available in Appendix C and Appendix D, respectively. Of the articles reviewed at full text, the most common reasons for exclusions were for outcomes (k=37), being conducted in a country not included on the “very high” list on the 2019 Human Development Index (k=30), study design (k=24), quality (k=23), or because the intervention was out of scope (k=20). Nine of the trials excluded due to intervention type were included in the prior review; however, due to the change in scope, studies of system-level policies and programs were excluded. Of the trials excluded for quality, most were found to have a high risk of bias due to missing outcome data and limited reporting around randomization procedures.

## Study and Population Characteristics

Study and population characteristics for all included studies can be found in Table 4.

Table 4 Study Characteristics, by Author

Author, Year, Quality | PR | KQs | Country | N Rand | General Population Description | Race and Ethnicity, % | Mean Age (range), years | Stage of Pregnancy^*^ | Primi % | Previously BF, % | Intending to BF, %
Abbass-Dick, 2015^122^; Good | X | KQ2 | Canada | 214 | General; (sociodemographics sparsely reported) | NR | 31 (18+) | Delivery | 100 | 0 | 100
Abbass-Dick, 2020^123^; Good | | KQ2, KQ3 | Canada | 113 | General; (sociodemographics sparsely reported) | NR | NR (18+) | Prenatal | NR | 0 | 100
Acar, 2024^124^; Fair | | KQ2, KQ3 | Turkey | 80 | General; (sociodemographics sparsely reported) | NR | 28 (18+) | Prenatal | 100 | 0 | 100
Addicks, 2019^125^; Fair | | KQ2 | US | 81 | Predominately White women, mixed SES | White: 89; Black: 4; Asian: 1; AI/AN: NR; Hispanic: 4; Other: 1; Multiracial: 1; Hispanic Ethnicity: 9 | 28 (18+) | Prenatal | 69 | 26 | 90
Anderson, 2005^126^; Fair | X | KQ1, KQ2 | US | 182 | Low-income, predominately urban Hispanic or Latina women | White: 7; Black: 18; Asian: NR; AI/AN: NR; Hispanic: 72; Other: 3 | NR (18+) | Prenatal | 52 | 40 | 100
Balaguer Martínez, 2018^127^; Fair | | KQ2 | Spain | 414 | Latina women, mixed SES | NR | 32 (18+) | Postpartum | 48 | 47 | NR
Baransel, 2024^128^; Fair | | KQ2, KQ3 | Turkey | 142 | General; (sociodemographics sparsely reported) | NR | 28 (18+) | Delivery | 100 | 0 | NR
Bender, 2022^129^; Good | | KQ1, KQ2 | US | 216 | Predominately Black or White women (SES NR) | White: 31; Black: 53; Asian: 8; AI/AN: NR; Hispanic: 13; Other: 3 | 32 (18+) | Prenatal | NR | NR | 94
Bernal, 2019^130^; Fair | | KQ2 | US | 40 | WIC-eligible, low-income Hispanic or Latina women | Hispanic: 100 | NR (NR) | Prenatal | 47 | 100 | NR
Bonuck, 2006^133^; Fair; MILK (Moms Into Learning about Kids) | X | KQ1, KQ2 | US | 382 | Predominately urban Hispanic or Latina or Black low-income women | White: NR; Black: 36; Asian: NR; AI/AN: NR; Hispanic: 57; Other: 7 | 25 (NR) | Prenatal | 40 | 42 | 77
Bonuck, 2014a^131^; Good; BINGO (Best Infant Nutrition for Good Outcomes) | X | KQ2 | US | 666 | Predominately urban Hispanic or Latina or Black low-income women | White: 5; Black: 29; Asian: 2; AI/AN: NR; Hispanic: 57; Other: 8 | 28 (18+) | Prenatal | 39 | 45 | 88
Bonuck, 2014b^132^; Good; Pairings (Provider Approaches to Improved Rates of Infant Nutrition and Growth Study) | X | KQ2 | US | 275 | Predominately Hispanic or Latina or Black women | White: 5; Black: 28; Asian: 3; AI/AN: NR; Hispanic: 56; Other: 8 | 28 (18+) | Prenatal | 44 | 49 | 94
Bunik, 2010^135^; Fair | X | KQ1, KQ2, KQ3 | US | 341 | Predominately Hispanic or Latina low-income women | White: 4; Black: 6; Asian: NR; AI/AN: NR; Hispanic: 88; Other: 2 | 22^†^ (18+) | Delivery | 100 | 0 | 100
Bunik, 2022^134^; Fair | | KQ2 | US | 469 | Predominately White women with higher education | White: 77; Black: 6; Asian: NR; AI/AN: NR; Hispanic: 17; Other: 17 | 28 (18+) | Prenatal | 100 | 0 | 0
Cangol, 2017^136^; Fair | | KQ2, KQ3 | Turkey | 100 | General; (sociodemographics sparsely reported) | NR | 22 (NR) | Prenatal | 100 | 0 | 85
Carlsen, 2013^137^; Fair | X | KQ2 | Denmark | 226 | Obese women; (sociodemographics sparsely reported) | NR | 32 (NR) | Delivery | 60 | NR | 100
Cauble, 2021^138^; Good | | KQ2 | US | 45 | Predominately White women, mixed SES | White: 95; Black: NR; Asian: NR; AI/AN: NR; Hispanic: NR; Other: NR | 26 (18 to 35) | Prenatal | 71 | NR | NR
Chan, 2016^139^; Good | | KQ2 | Hong Kong | 71 | Chinese women, predominately higher education | Asian: 100 | 32 (NR) | Prenatal | 100 | 0 | 100
Chapman, 2013^140^; Fair | X | KQ1, KQ2 | US | 206 | Overweight/obese, low-income, predominately Hispanic or Latina women | White: 5; Black: 10; Asian: NR; AI/AN: NR; Hispanic: 82; Other: 3 | 24^†^ (18+) | Prenatal | NR | NR | 100
Clarke, 2020^141^; Fair; ABA (Assets-Based feeding help Before and After birth) | | KQ1, KQ2, KQ3 | Great Britain | 103 | Predominately White women from socioeconomically disadvantaged neighborhoods | White: 92; Black: 2; Asian: 1; AI/AN: NR; Hispanic: NR; Other: 1 | 29 (16 to 43) | Prenatal | 0 | 0 | 85
Dennis, 2002^142^; Fair | X | KQ2, KQ3 | Canada | 258 | General; (sociodemographics sparsely reported) | NR | NR (16+) | Delivery | 100 | 0 | 100
Di Meglio, 2010^143^; Fair | X | KQ2 | US | 78 | Younger (<21 years), predominately Black or White low-income women | White: 47; Black: 50; Asian: NR; AI/AN: NR; Hispanic: 13; Other: 3 | 18 (<20) | Delivery | 87 | 9 | 71
Di Napoli, 2004^144^; Fair | X | KQ2 | Italy | 605 | General; (sociodemographics sparsely reported) | NR | 31 (18 to 47) | Delivery | 44 | 37 | 100
Edwards, 2013^145^; Fair | X | KQ2 | US | 248 | Younger (<21 years) Black women, predominately lower income | White: 0; Black: 100; Asian: 0; AI/AN: 0; Hispanic: NR; Other: NR | 18 (<21) | Prenatal | 89 | NR | 62
Elliott-Rudder, 2014^146^; Good | X | KQ2 | Australia | 330 | Women breastfeeding for at least 8 weeks | NR | NR (NR) | Postpartum | 36 | 44 | NR
Fan, 2022^147^; Fair | | KQ2 | Hong Kong | 33 | Chinese women, predominately higher education | NR | 33 (NR) | Prenatal | 100 | 0 | 100
Fiks, 2017^148^; Fair; The Grow2Gether Intervention study | | KQ2 | US | 87 | Overweight/obese, low-income, predominately Black women | White: 6; Black: 88; Asian: NR; AI/AN: NR; Hispanic: 2; Other: 7 | 26 (18+) | Prenatal | 17 | NR | NR
Forster, 2004^149^; Fair | X | KQ2 | Australia | 984 | Low-income, culturally diverse women (sparse demographic data) | NR | 28 (NR) | Prenatal | 100 | 0 | 93
Forster, 2019^150^; Good; RUBY (Ringing up About Breastfeeding) | | KQ2, KQ3 | Australia | 1,157 | General; (sociodemographics sparsely reported) | NR | 31 (NR) | Delivery | 100 | 0 | 100
Franco-Antonio, 2020^151^; Good | | KQ1, KQ2 | Spain | 88 | General; (sociodemographics sparsely reported) | NR | 33 (NR) | Delivery | 34 | 60 | NR
Fu, 2014^152^; Fair | X | KQ2 | Hong Kong | 724 | Chinese women, predominately higher education | Asian: 100 | 31 (18+) | Delivery | 100 | 0 | 100
Gagnon, 2002^153^; Fair | X | KQ1, KQ2, KQ3 | Canada | 586 | General; (sociodemographics sparsely reported) | NR | 30 (NR) | Delivery | 33 | NR | 89
Gijsbers, 2006^154^; Fair | X | KQ2 | Netherlands | 91 | Women with a family history of asthma | NR | 31 (NR) | Prenatal | 42 | 54 | 87
Graffy, 2004^155^; Fair | X | KQ2, KQ3 | Great Britain | 720 | Predominately White women, mixed SES | White: 70; Black: 16; Asian: 8; AI/AN: NR; Hispanic: NR; Other: 7 | NR (NR) | Prenatal | 75 | NR | 97
Gross, 2016^156^; Fair; StEP (The Starting Early Program) | | KQ2, KQ3 | US | 533 | Hispanic or Latina women, predominately low-income | Hispanic: 100 | 28 (18+) | Prenatal | 37 | NR | NR
Hans, 2018^157^; Fair | | KQ1, KQ2 | US | 312 | Predominately Hispanic or Latina or Black low-income women meeting criteria for high social risk | White: 8; Black: 45; Asian: NR; AI/AN: NR; Hispanic: 38; Other: NR | 18 (<26) | Prenatal | 98 | NR | NR
Henderson, 2001^158^; Good | X | KQ2, KQ3 | Australia | 160 | General; (sociodemographics sparsely reported) | NR | 27 (NR) | Delivery | 100 | 0 | 100
Hoffmann, 2019^159^; Fair; Healthy living in pregnancy (GeliS [Gesund leben in der Schwangerschaft]) trial | | KQ1, KQ2 | Germany | 2,261 | General; (sociodemographics sparsely reported) | NR | 30 (18 to 43) | Prenatal | 58 | NR | NR
Hopkinson, 2009^160^; Good | X | KQ1, KQ2, KQ3 | US | 522 | Predominately Hispanic or Latina women | White: NR; Black: NR; Asian: NR; AI/AN: NR; Hispanic: 98; Other: NR | 27 (NR) | Delivery | NR | NR | NR
Howell, 2014^161^; Fair | X | KQ2 | US | 540 | Predominately Hispanic or Latina or Black low-income women | White: 0; Black: 38; Asian: 0; AI/AN: 0; Hispanic: 62; Other: 0 | 28 (18 to 46) | Delivery | 41 | NR | NR
Jolly, 2012^162^; Fair | X | KQ2, KQ3 | Great Britain | 2,724 | Predominately of Asian or Middle Eastern origin living in deprived, urban areas | White: 9; Black: 15; Asian: 65; AI/AN: NR; Hispanic: NR; Other: 11 | NR (NR) | Prenatal | 34 | 46 | 81
Karaahmet, 2022^163^; Fair | | KQ2 | Turkey | 158 | General; (sociodemographics sparsely reported) | NR | 26 (18 to 35) | Delivery | 100 | 0 | NR
Kellams, 2015^164^; Good | X | KQ2 | US | 522 | Low-income, predominately Black or White women | White: 42; Black: 45; Asian: NR; AI/AN: NR; Hispanic: 8; Other: 5 | 25 (NR) | Prenatal | NR | NR | 67
Kenyon, 2016^165^; Fair | | KQ1, KQ2 | Great Britain | 1,324 | Women reporting social risk factors, predominately British or Asian ethnicity | White: NR; Black: NR; Asian: NR; AI/AN: NR; Hispanic: NR; Other: 7 | 22^†^ (16+) | Prenatal | NR | NR | NR
Kools, 2005^166^; Fair | X | KQ2 | Netherlands | 781 | General; (sociodemographics sparsely reported) | NR | 31 (19 to 43) | Prenatal | 56 | 29 | 68
Kronborg, 2012^167^; Fair | X | KQ2, KQ3 | Denmark | 1,193 | General; (sociodemographics sparsely reported) | NR | 29 (18+) | Prenatal | 100 | 0 | NR
Labarere, 2003^168^; Good | X | KQ2, KQ3 | France | 210 | General; (sociodemographics sparsely reported) | NR | 31 (18+) | Delivery | 53 | NR | NR
Labarere, 2005^169^; Good | X | KQ2, KQ3 | France | 231 | General; (sociodemographics sparsely reported) | NR | 30 (NR) | Delivery | 52 | NR | NR
Laliberté, 2016^170^; Fair | | KQ1, KQ2 | Canada | 472 | General, predominately higher education | NR | NR | Delivery | 62 | NR | 100
Lavender, 2005^171^; Fair | X | KQ2 | Great Britain | 1,312 | Predominately White women, lower income | White: 92; Black: NR; Asian: NR; AI/AN: NR; Hispanic: NR; Other: NR | 30 (NR) | Prenatal | 51 | NR | 100
Lewkowitz, 2018^173^; Fair | | KQ2 | US | 118 | Overweight/obese, Black low-income women | Black: 100 | NR (18 to 45) | Prenatal | NR | NR | NR
Lewkowitz, 2020^172^; Good; BFF (Breastfeeding Friend) | | KQ2 | US | 170 | Predominately Black, low-income women | White: 11; Black: 82; Asian: 1,; AI/AN: NR; Hispanic: 2; Other: 4 | 22 (NR) | Prenatal | 100 | 0 | 54
Linares, 2019^174^; Fair; Las Dos Casas (breastfeeding supplemented with formula) | | KQ2 | US | 39 | Immigrant Hispanic or Latina women, predominately low-income | Hispanic: 100 | 25 (NR) | Prenatal | NR | NR | 100
Little, 2021^175^; Fair | | KQ2, KQ3 | US | 100 | Predominately Hispanic or Latina low-income women | White: NR; Black: NR; Asian: NR; AI/AN: NR; Hispanic: 95; Other: NR | 26 (18+) | Prenatal | 29 | 64 | NR
Lucas, 2019^176^; Fair | | KQ2, KQ3 | US | 65 | Predominately White women, mixed SES | White: 77; Black: 11; Asian: 5,; AI/AN: NR; Hispanic: 13; Other: NR | 30 (18 to 45) | Delivery | 41 | 54 | 100
Lutenbacher, 2022^177^; Good | | KQ1, KQ2, KQ3 | US | 132 | Hispanic or Latina women, predominately low-income | Hispanic: 100 | 30 (18+) | Prenatal | 4 | 68 | NR
Mattar, 2007^178^; Fair | X | KQ2 | Singapore | 401 | Predominately Southeast Asian women with lower income | White: NR; Black: NR; Asian: 98; AI/AN: NR; Hispanic: NR; Other: 2 | NR (NR) | Prenatal | 37 | 64 | 95
McDonald, 2010^179^; Good | X | KQ2, KQ3 | Australia | 849 | General; (sociodemographics sparsely reported) | NR | NR (NR) | Delivery | 50 | NR | 100
McLachlan, 2016^180^; Fair; SILC (Supporting breastfeeding In Local Communities) | | KQ2 | Australia | 9,675 | Women who initiated breastfeeding after delivery | NR | 31 (NR) | Postpartum | 41 | NR | NR
McQueen, 2011^181^; Good | X | KQ2 | Canada | 150 | Predominately White women (14% Aboriginal) with higher education | White: 81; Black: NR; Asian: NR; AI/AN: NR; Hispanic: NR; Other: 5 | NR (NR) | Delivery | 100 | 0 | 100
Milinco, 2020^182^; Fair | | KQ2, KQ3 | Italy | 208 | General; (sociodemographics sparsely reported) | NR | NR (NR) | Prenatal | 60 | 91 | 100
Miremberg, 2022^183^; Fair | | KQ2 | Israel | 224 | General; (sociodemographics sparsely reported) | NR | 32 (18 to 45) | Delivery | 29 | 64 | 100
Mottl-Santiago, 2023^184^; Good | | KQ2 | US | 411 | Low-income, predominately Black or Hispanic women | White: 7; Black: 35; Asian: 4; AI/AN: 0; Hispanic: 49; Other: 5 | 25 (18+) | Prenatal | 100 | 0 | NR
Muirhead, 2006^185^; Fair | X | KQ2 | Great Britain | 225 | General; (sociodemographics sparsely reported) | NR | 28 (16 to 43) | Prenatal | 53 | 24 | 52
Nilsson, 2017^186^; Fair | | KQ1, KQ2, KQ3 | Denmark | 3,541 | General; (sociodemographics sparsely reported) | NR | 30 (NR) | Prenatal | 40 | NR | 100
Noel-Weiss, 2006^187^; Fair | X | KQ2 | Canada | 101 | General; (sociodemographics sparsely reported) | NR | 30 (17 to 42) | Prenatal | 100 | 0 | 100
O’Reilly, 2024^188^; Good; Latch ON | | KQ2 | Ireland | 225 | Predominantly White women with BMI ≥25 kg/m^2^ | White: 78; Black: NR; Asian: NR; AI/AN: NR; Hispanic: NR; Other: NR | 43 (18+) | Prenatal | 100 | 0 | 97
Paul, 2012^189^; Fair; NITTANY | X | KQ2 | US | 1,154 | Predominately White women, mixed SES | White: 88; Black: 6; Asian: 4; AI/AN: NR; Hispanic: 5; Other: 1 | 29 (NR) | Delivery | 48 | 49 | 100
Pollard, 2011^190^; Good | X | KQ2 | US | 86 | Predominately White women, mixed SES | White: 97; Black: NR; Asian: NR; AI/AN: NR; Hispanic: NR; Other: 4 | 26 (18 to 40) | Delivery | 100 | 0 | 100
Puharic, 2020^191^; Fair | | KQ1, KQ2, KQ3 | Croatia | 272 | General (sociodemographics sparsely reported) | NR | NR (NR) | Prenatal | 100 | 0 | 99
Quinlivan, 2003^192^; Fair | X | KQ2 | Australia | 136 | Adolescents (<18 years), predominately low-income, 24% indigenous Australian | NR | 16 (<18) | Prenatal | NR | NR | NR
Reeder, 2014^193^; Fair | X | KQ2 | US | 1,948 | WIC-eligible, low-income predominately Hispanic or Latina or White women | NR | 27 (NR) | Prenatal | NR | NR | NR
Saglik, 2021^194^; Fair | | KQ2, KQ3 | Turkey | 70 | Women with at least primary education | NR | 27 (18 to 35) | Prenatal | NR | 52 | NR
Santamaria-Martin, 2022^195^; Fair; PROLACT | | KQ2 | Spain | 434 | Women exclusively breastfeeding for at least 4 weeks | NR | 33 (18+) | Postpartum | 58 | 100 | NR
Sari, 2020^196^; Fair | | KQ1, KQ2 | Turkey | 88 | General; (sociodemographics sparsely reported) | NR | 28 (20 to 35) | Prenatal | 100 | 0 | NR
Sari Ozturk, 2023^197^; Good | | KQ1, KQ2 | Turkey | 66 | General; (sociodemographics sparsely reported) | NR | 29 (19 to 37) | Prenatal | 100 | NR | NR
Saucedo Baza, 2023^198^; Fair | | KQ2 | US | 40 | Racially diverse, mixed SES | White: 43; Black: 48; Asian: 3; AI/AN: NR; Hispanic: 8; Other: NR | 25 (16 to 37) | Delivery | NR | NR | 100
Schwarz, 2024; Fair | | KQ2 | US | 472 | Racially diverse, generally higher SES | White: 60; Black: 20; Asian: 6; AI/AN: 1; Hispanic: 5; Other: 7 | 32 (NR) | Prenatal | 100 | 0 | 96
Sevda, 2023^200^; Fair | | KQ2, KQ3 | Turkey | 150 | General; (sociodemographics sparsely reported) | NR | 25 (18+) | Prenatal | 100 | 0 | NR
Simsek-Cetinkaya, 2024^201^; Fair | | KQ1, KQ3 | Turkey | 81 | General; (sociodemographics sparsely reported) | NR | 33 (18 to 35) | Prenatal | 100 | 0 | 100
Stockdale, 2008^202^; Fair | X | KQ2 | Ireland | 182 | General; (sociodemographics sparsely reported) | NR | NR (NR) | Prenatal | 100 | 0 | NR
Su, 2007^203^; Fair | X | KQ2 | Singapore | 450 | Southeast Asian women (48% Malay, 38% Chinese, 11% Indian), predominantly low-income | Asian: 100 | 30 (NR) | Delivery | 40 | 56 | 100
Taylor, 2017^204^; Fair | | KQ2 | New Zealand | 428 | General, predominately higher education | NR | 32 (16+) | Prenatal | 48 | NR | NR
Uscher-Pines, 2020^205^; Good; Tele-MILC | | KQ2 | US | 203 | Rural, predominately White women, mixed SES | White: 96; Black: NR; Asian: NR; AI/AN: NR; Hispanic: 2; Other: NR | 27 (18+) | Delivery | 40 | 57 | 100
Wallace, 2006^206^; Fair | X | KQ2, KQ3 | Great Britain | 370 | General; (sociodemographics sparsely reported) | NR | NR (NR) | Delivery | 100 | 0 | 100
Wambach, 2011^207^; Fair | X | KQ2 | US | 390 | Adolescents (15-18 years), predominately Black and from low-income families | White: NR; Black: 61; Asian: NR; AI/AN: NR; Hispanic: NR; Other: NR | 17 (15 to 18) | Prenatal | 100 | 0 | NR
Wen, 2011^208^; Good | X | KQ2 | Australia | 667 | General; (sociodemographics sparsely reported) | NR | 26 (16 to 47) | Prenatal | 100 | 0 | NR
Wen, 2020^209^; Good; CHAT (Communicating Healthy Beginnings Advice by Telephone) | | KQ2 | Australia | 1,155 | General; (sociodemographics sparsely reported) | NR | 32 (16+) | Prenatal | 46 | NR | NR
Wong, 2014^210^; Good | X | KQ2 | Hong Kong | 469 | Cantonese-speaking women, predominately higher education and income | Asian: 100 | 31 (18+) | Prenatal | 100 | 0 | 100
Yesil, 2023^211^; Good | | KQ2 | Turkey | 90 | General; (sociodemographics sparsely reported) | NR | 29 (18 to 43) | Delivery | 36 | 50 | NR

Abbreviations: AI/AN = American Indian or Alaska Native; BF = breastfeed(ing); BL = baseline; KQ = key question; Prev Inc = included in prior review; Rand = randomized; N = number; NA = not applicable; NR = not reported; PR = included in the prior review; Primi = Primiparous; SES = socioeconomic status; WIC = Women, Infants, and Children program; US = United States.

* Stage of pregnancy at time of recruitment. “Delivery” reflects at or around the time of delivery.

† Median.

All 90 of the included studies were RCTs; 10 were cluster RCTs with randomization of hospitals,^152,^ ^186^ family practice or general practice clinics,^146,^ ^154,^ ^162^ maternal and child home healthcare organizations,^166^ local government areas or electoral wards,^159,^ ^171,^ ^180^ and community health and wellness centers.^195^ Just over a third of the studies (33/90, 37%) were conducted in the United States and 23 studies took place in European countries (26%), including seven studies in the United Kingdom. The remaining studies took place in Australia (9 studies, 10%), countries in Asia (17 studies, 19%), and Canada (7 studies, 8%). The sample sizes of the studies ranged considerably from 39 women in one study to 9,675 women in another study. The median sample size was 229 across the studies. Most of the cluster RCTs had more than 2,000 women enrolled.

The inclusion criteria for women allowed in the studies was highly variable across individual studies, and the demographic information of the included samples was often sparsely reported. Among studies that reported the mean age of included women, the average age ranged from 16 to 33 years and the median of the average age was 28 years. Four studies were limited to adolescents (age <18 years)^192,^ ^207^ or young adults (age <21 years).^143,^ ^145^

Most studies recruited women during pregnancy (57/90 studies, 63%) or shortly following delivery within the birthing facility (29/90, 32%). Five studies enrolled women during the postpartum period (up to 8 weeks postpartum) and required that women had initiated or were exclusively breastfeeding at the time of recruitment.^127,^ ^146,^ ^170,^ ^180,^ ^195^ Almost half of the studies (40/90, 44%) required that women be intending to breastfeed to be eligible for study inclusion; in the remaining studies that reported it, most women intended to breastfeed at the beginning of the trials. Many studies required that this was the women’s first live birth and therefore, they had no previous breastfeeding experience. Of those who had previous births, the proportion with previous experience breastfeeding ranged from 9 percent to 100 percent. Almost all studies explicitly stated the exclusion of women or infants with conditions that would preclude or complicate breastfeeding, such as an infant congenital abnormality.

The demographic and social characteristics of the included samples, and the reporting of those characteristics, were extremely mixed. Among the 33 studies taking place in the United States, most (24/33, 73%) included mostly women of color. Of these trials, four limited inclusion to Hispanic or Latina women^130,^ ^156,^ ^174,^ ^177^ and two limited inclusion to Black women, including one among Black women living with overweight or obesity.^145,^ ^173^ In the remaining 18 studies, participants were predominately Black and/or Hispanic and Latina women.^126,^ ^129,^ ^131–133,^ ^135,^ ^140,^ ^143,^ ^148,^ ^157,^ ^160,^ ^161,^ ^164,^ ^172,^ ^175,^ ^184,^ ^193,^ ^207^ Furthermore, within these 24 studies, many studies required that women be within lower income categories to participate (e.g., WIC-eligible [income of 185% or less of the federal poverty income guidelines], Medicaid recipient) or those recruited were generally of lower income groups. The remaining seven U.S.-based studies reported including patients who identified as White women or of variable races and ethnicities.^125,^ ^134,^ ^138,^ ^176,^ ^189,^ ^190,^ ^198,^ ^199,^ ^205^ Where reported, few women in the U.S.-based studies were of Asian/Pacific Islander or Native American decent.

In the 57 non-U.S.-based studies, demographic and social characteristics were more sparsely reported. In seven studies, all or predominately all women were of Asian or Middle Eastern descent; these studies were conducted in Hong Kong, Singapore, and the United Kingdom.^180,^ ^181,^ ^192^ A few studies in Australia and Canada noted the proportion of women who were Aboriginal or Torres Strait Islander people, ranging from 1 percent to 24 percent.^180,^ ^181,^ ^192^ One additional study in Australia noted that the sample represented “low-income, culturally diverse women” but more detailed demographic data were not reported.^149^ Likewise, two studies in the United Kingdom recruited women from “deprived urban areas,” with one study predominantly including women of Asian or Middle Eastern origin.^162,^ ^171^

Within all the studies, fewer than half reported variables such as employment status, intentions to return to work, or marital or cohabitation status. In those that did, prenatal employment (i.e., working part-time or full-time) ranged from 5 percent to 88 percent of the sample and most women expressed an intention to return to work after unpaid or paid parental leave. In studies that reported relationship status, most women reported being married or cohabitating.

In addition to studies limited to women belonging to certain racial or ethnic groups or falling within a particular socioeconomic demographic, several studies limited inclusion based on health status or living situation. In five trials, participation was limited to women living with overweight or obesity.^137,^ ^140,^ ^148,^ ^173,^ ^188^ One trial was limited to women who had a family history of asthma.^154^ In two studies, trial enrollment was limited to women who had a male partner who could participate in the study because the focus of the interventions was effective coparenting.^122,^ ^123^

## Intervention and Control Characteristics

A summary and details of each included intervention can be found in Table 5 and Appendix E Table 1, respectively. Given the variability in the interventions, we discuss the interventions in two main groups: 1) those that focused on breastfeeding education and support alone, and 2) those that included breastfeeding support in addition to content related to other maternal or infant topics (named “breastfeeding plus”).

Table 5 Intervention Characteristics, by Author and Focus of Intervention

Author, Year, Country | Group | Brief Description | Timing of Intervention | Duration (weeks) | Intervention Dose | Interventionist(s)
BREASTFEEDING SUPPORT ONLY INTERVENTIONS
Abbass-Dick, 2015^122^; Canada | IG1 | Coparenting workbook, website, and professional breastfeeding support | Peripartum, Postpartum | 3 | 1 × 15 min in-hospital postpartum coparenting counseling session | Lactation care provider
Abbass-Dick, 2020^123^; Canada | IG1 | Web-based coparenting breastfeeding education | Prenatal, Peripartum, Postpartum | 52 | 6 weekly e-mail reminders about access to the website and 52 weeks of passive access to the website | NA
Acar, 2024^124^; Turkey | IG1 | Mobile application-based breastfeeding support | Peripartum, Postpartum | 8 | 8 weeks of access to a mobile application | NA
Addicks, 2019^125^; US | IG1 | Motivational interviewing | Prenatal | 0.7 | 1 × 45-min in-person MI session | Therapist
Anderson, 2005^126^; US | IG1 | Peer home-visiting breastfeeding support | Prenatal, Peripartum, Postpartum | 14 | 3 × 85-min prenatal home visits; Daily in-hospital visits; 9 × postpartum home visits; Breastfeeding video; + optional phone support | Peer counselor
Balaguer Martínez, 2018^127^; Spain | IG1 | Professional phone-based breastfeeding support | Postpartum | 26 | 16 telephone calls (minutes NR) | Nurse
Baransel, 2024^128^; Turkey | IG1 | Professional education and text message support | Peripartum, Postpartum | 6 | 2 × 25 min in-person sessions; Daily text messages | Midwife
Bender, 2022^129^; US | IG1 | Text message breastfeeding information and support | Peripartum, Postpartum | 6 | 1 × text message weekly for 6 weeks; + optional on-demand daily text-based support | Physician
Bernal, 2019^130^; US | IG1 | Peer telephone breastfeeding support | Prenatal, Peripartum, Postpartum | 12 | ≤ 7 × 40 min phone calls | Peer counselor
Bonuck, 2006^133^; US | IG1 | Professional in-person breastfeeding support | Prenatal, Peripartum, Postpartum | 68 | 2 × 60 min prenatal visits; In-hospital visits; 1 × 90 min postpartum home visit; + optional followup phone support for a year; + nursing bra; + manual or electronic breast pump | Lactation care provider
Bonuck, 2014a^131^ (BINGO); US | IG1 | Professional in-person and telephone breastfeeding support and EHR-prompts to facilitate support | Prenatal, Peripartum, Postpartum | 24 | 5 × brief prenatal education sessions; 2 × 45 min prenatal sessions; 1 × 15 min in-hospital visit; 1 × 15 min postpartum pediatric session; ≤12 postpartum phone calls; + 1 × 15 min optional postpartum home visit; + optional nursing bra; + optional breast pump | Lactation care provider (IBCLC) and physician or midwife
Bonuck, 2014a^131^ (BINGO); US | IG2 | Professional in-person and telephone breastfeeding support | Prenatal, Peripartum, Postpartum | 24 | 2 × 45 min prenatal sessions; 1 × 15 min in-hospital visit; 1 × 15 min postpartum pediatric session; ≤12 postpartum phone calls; 1 × 15 min optional postpartum home visit; + optional nursing bra; + optional breast pump | Lactation care provider (IBCLC)
Bonuck, 2014a^131^ (BINGO); US | IG3 | EHR-prompts to facilitate professional breastfeeding support | Prenatal | 12 | 5 × brief prenatal education sessions | Physician or midwife
Bonuck, 2014b^132^ (PAIRINGS); US | IG1 | Professional in-person and telephone breastfeeding support | Prenatal, Peripartum, Postpartum | 24 | 5 × brief prenatal education sessions; 2 × 45 min prenatal sessions; 1 × 15 min in-hospital visit; 1 × 15 min postpartum pediatric session; ≤12 postpartum phone calls; + 1 × 15 min optional postpartum home visit; + optional nursing bra; + optional breast pump | Physician or midwife and lactation care provider (IBCLC)
Bunik, 2010^135^; US | IG1 | Professional telephone breastfeeding support | Postpartum | 2 | 14 × postpartum phone calls | Nurse
Bunik, 2022^134^; US | IG1 | Text message-based breastfeeding support | Prenatal, Postpartum | 16 | 60 × daily text message prompts (20 delivered prenatally, 40 delivered postpartum) | NA
Cangol, 2017^136^; Turkey | IG1 | Professional in-person breastfeeding support | Prenatal, Peripartum, Postpartum | 14 | NR | NR
Carlsen, 2013^137^; Denmark | IG1 | Professional telephone breastfeeding support | Postpartum | 26 | ≥9 × 5-20 min postpartum phone sessions | Lactation care provider (IBCLC)
Cauble, 2021^138^; US | IG1 | Group, telephone breastfeeding education | Prenatal | 6 | 6 × 60 min group counseling telephone sessions | Lactation care provider (IBCLC) and registered dietitian
Chan, 2016^139^; Hong Kong | IG1 | Group breastfeeding education + professional telephone counseling | Prenatal, Postpartum | 14 | 1× 150-min in-person session; 1 × 30-60 minute phone call | Research staff
Chapman, 2013^140^; US | IG1 | Peer clinic and home-visiting and telephone breastfeeding support | Prenatal, Peripartum, Postpartum | 30 | 3 × 60-90 min prenatal visits; ≥1 in-hospital visits; ≤11 postpartum home visits; ≥ 1 postpartum phone calls; + electric breast pump | Peer counselor
Clarke, 2020^141^; UK | IG1 | Peer in-person, text, and telephone breastfeeding support | Prenatal, Postpartum | 40 | 1 × prenatal in-person session; Monthly prenatal monthly telephone/text messages; Daily postpartum telephone/text message contact for first 2 weeks, monthly text messages months 3-5; + In-person visits arranged as needed | Peer counselor
Dennis, 2002^142^; Canada | IG1 | Peer telephone breastfeeding support | Postpartum | 26 | 5 × 15 min postpartum phone calls | Peer counselor
Di Meglio, 2010^143^; US | IG1 | Peer telephone breastfeeding support | Postpartum | 5 | 7 × postpartum telephone support calls | Peer counselor
Di Napoli, 2004^144^; Italy | IG1 | Professional home-visiting and telephone breastfeeding support | Postpartum | 1 | 1 × 30 min postpartum home visit; 1 × postpartum phone call | Midwife
Elliott-Rudder, 2014^146^; Australia | IG1 | Professional in-person support to continue breastfeeding | Postpartum | 0.14 | 1 × postpartum counseling session | Nurse
Fan, 2022^147^; Hong Kong | IG1 | Peer text-messaging breastfeeding support | Postpartum | 26 | 26 weeks on online support via WhatsApp | Peer counselor
Forster, 2004^149^; Australia | IG1 | Group breastfeeding education (attitude modification focus) | Prenatal | 2 | 2 × 60 min prenatal group sessions | Midwife and community educator
Forster, 2004^149^; Australia | IG2 | Group breastfeeding education (practical skills training focus) | Prenatal | 0.14 | 1 × 90 min prenatal group session | Midwife and community educator
Forster, 2019^150^; Australia | IG1 | Peer telephone breastfeeding support | Postpartum | 26 | ≤17 (average of 6) × 12 min phone calls | Peer counselor
Franco-Antonio, 2020^151^; Spain | IG1 | Professional in-person and telephone breastfeeding support | Peripartum, Postpartum | 24 | 1 × 20-30 min in-person session; 3 × 15 min phone calls; + printed leaflet | Midwife
Fu, 2014^152^; Hong Kong | IG1 | Professional telephone breastfeeding support | Postpartum | 4 | 4 × 20 min postpartum phone counseling sessions | Nurse
Fu, 2014^152^; Hong Kong | IG2 | Professional in-hospital breastfeeding support | Peripartum | 0.42 | 3 × 30 min in-hospital postpartum counseling sessions | Nurse
Gagnon, 2002^153^; Canada | IG1 | Professional home-visiting breastfeeding support | Postpartum | 0.14 | 1 × 60 min postpartum home visit; + optional followup support | Nurse
Gijsbers, 2006^154^; Netherlands | IG1 | Professional home-visiting breastfeeding support | Prenatal, Postpartum | 26 | 2 × 60 min prenatal home sessions; 1 × 60 min postpartum home session; + breastfeeding booklet | Research staff
Graffy, 2004^155^; UK | IG1 | Peer in-person and telephone breastfeeding support | Prenatal | 0.14 | 1 × prenatal clinic visit; + optional postpartum phone support; + optional postpartum home visits; + print materials | Peer counselor
Henderson, 2001^158^; Australia | IG1 | Professional in-hospital breastfeeding support | Peripartum | 0.14 | 1 × 30 min in-hospital support session; + additional technical support sessions while in the hospital | Research staff
Hopkinson, 2009^160^; US | IG1 | Professional in-person breastfeeding support | Postpartum | 0.14 | 1 × 60 min postpartum session; + optional followup visits and/or phone calls | Breastfeeding counselor
Jolly, 2012^162^; UK | IG1 | Peer clinic and home-visiting and telephone breastfeeding support | Prenatal, Postpartum | 17 | 3 × prenatal clinic or home visits; ≥1 × postpartum home visits; + optional phone support | Peer counselor
Karaahmet, 2022^163^; Turkey | IG1 | Professional hands-on support, written materials, and counseling | Peripartum, Postpartum | 24 | 1 × in-person breastfeeding demonstration and support session + written materials + online help | Health professional (NR)
Kellams, 2015^164^; US | IG1 | Educational breastfeeding video | Prenatal | 0.14 | 1 × 25 min educational video | NA
Kools, 2005^166^; Netherlands | IG1 | Professional home-visiting and telephone breastfeeding support and printed workbook | Prenatal, Postpartum | 16 | 1 × 17 min prenatal home visit; ≥2 × 9 min postpartum home visits; + optional phone sessions + booklet | Physician, nurse, and lactation care provider
Kronborg, 2012^167^; Denmark | IG1 | Group breastfeeding education | Prenatal | 5 | 3 × 180 min prenatal group sessions | Midwife
Labarere, 2003^168^; France | IG1 | Professional in-person breastfeeding education | Peripartum | 0.14 | 1 × 30 min in-hospital education session; + optional peer support group | Midwife
Labarere, 2005^169^; France | IG1 | Professional in-person breastfeeding support | Postpartum | 0.14 | 1 × postpartum session | Pediatrician or primary care physician
Lavender, 2005^171^; UK | IG1 | Group breastfeeding education | Prenatal | 0.14 | 1 × 150 min prenatal group session | Infant feeding coordinator
Lewkowitz, 2020^172^; US | IG1 | App-based breastfeeding education | Prenatal, Peripartum, Postpartum | 16 | 16 weeks of app-based on-demand breastfeeding and education support | NA
Linares, 2019^174^; US | IG1 | Peer and professional home-visiting and telephone breastfeeding support | Prenatal, Postpartum | 24 | 2 × 30-40 min prenatal home visit session; 3 × 10-15 min prenatal phone calls; 1 × 20-30 min hospital visit; 2 × 40-60 min postpartum home visit; 6 × 10-20 min postpartum phone calls | Peer counselor and lactation care provider (IBCLC)
Little, 2021^175^; US | IG1 | Received an infant carrier | Prenatal | 0.14 | 1 × in-person session | Community educator
Lucas, 2019^176^; US | IG1 | App-based breastfeeding education and support | Postpartum | 6 | 2 × text messages a week for 6 weeks; 7 × 5-minute modules; 6 journal prompts/day × 2 weeks; 1 journal prompt/day × 4 weeks | Nurse
Mattar, 2007^178^; Singapore | IG1 | Video-based breastfeeding education and printed materials | Prenatal | 0.14 | 1 × 15 min prenatal session with lactation consultant; + prenatal video and booklet | Lactation care provider
Mattar, 2007^178^; Singapore | IG2 | Video-based breastfeeding education and printed materials | Prenatal | 0.14 | Prenatal video and booklet | NA
McDonald, 2010^179^; Australia | IG1 | Professional in-person and telephone breastfeeding support | Peripartum, Postpartum | 6 | 1 × in-hospital education session; ≤6 postpartum home visits; ≤12 postpartum phone calls | Midwife
McLachlan, 2016^180^; Australia | IG1 | Professional home-visiting breastfeeding support plus access to a breastfeeding support center | Postpartum | 52 | ~3 × 60-70 min sessions | Nurse
McLachlan, 2016^180^; Australia | IG2 | Professional home-visiting breastfeeding support | Postpartum | 52 | ~2 × 60-70 min sessions | Nurse
McQueen, 2011^181^; Canada | IG1 | Professional in-person and telephone breastfeeding support | Peripartum, Postpartum | 2 | 2 × in-hospital sessions; 1 × postpartum phone call | Nurse
Milinco, 2020^182^; Italy | IG1 | Professional breastfeeding support and video to promote a biological nurturing approach to decrease breastfeeding problems | Peripartum | 0.14 | 1 video | Nurse and midwife
Miremberg, 2022^183^; Israel | IG1 | App-based, individualized professional breastfeeding support | Peripartum, Postpartum | 24 | On-demand access to web-based smartphone app for 24 weeks | Lactation care provider (certified by Israeli Ministry of Health), clinical psychologist, and nurse
Muirhead, 2006^185^; UK | IG1 | Peer in-person and telephone breastfeeding support | Prenatal, Postpartum | 16 | ≥1 × prenatal visit; ≥14 × postpartum home visits or phone calls | Peer counselor
Nilsson, 2017^186^; Denmark | IG1 | Co-parenting professional breastfeeding support | Prenatal, Peripartum, Postpartum | 6 | 1 prenatal counseling session with written support; 1 postpartum phone call; Postpartum counseling (varied) | Midwife
Noel-Weiss, 2006^187^; Canada | IG1 | Group breastfeeding education | Prenatal | 0.14 | 1 × 180 min prenatal group session | NR
O’Reilly, 2024^188^; Ireland | IG1 | Professional breastfeeding education and support | Prenatal, Peripartum, Postpartum | 6 | 1 × in-person group session; 1 × in-person individual session; 6 × postpartum phone calls | Lactation care provider (IBCLC)
Pollard, 2011^190^; US | IG1 | Completion of a feeding log to self-monitor breastfeeding | Peripartum, Postpartum | 6 | Instructions for completing a daily breastfeeding log | Research staff
Puharic, 2020^191^; Croatia | IG1 | Professional telephone breastfeeding support and printed educational materials | Prenatal, Postpartum | 20 | 4 × telephone sessions; + printed materials | Nurse
Reeder, 2014^193^; US | IG1 | Peer telephone breastfeeding support | Prenatal, Postpartum | 18 | 2 × prenatal phone calls; 2-6 × postpartum phone calls; + print materials | Peer counselor
Saglik, 2021^194^; Turkey | IG1 | Professional in-person breastfeeding support | Prenatal, Peripartum, Postpartum | 12 | NR | Lactation care provider (certified by National breastfeeding counseling program)
Santamaria-Martin, 2022^195^; Spain | IG1 | Group breastfeeding education | Postpartum | 6 | 6 × 120 min group sessions | Healthcare professional
Sari, 2020^196^; Turkey | IG1 | Web-based breastfeeding education | Prenatal | 8 | 4 × on-demand web-based videos and support; 2 × in-person postpartum appointments | Health professional
Sari Ozturk, 2023^197^; Turkey | IG1 | Technology-based support with phone counseling | Prenatal | 8 | 3 educational models with 4 art-based activities + followup phone counseling after each module | Research staff
Saucedo Baza, 2023^198^; US | IG1 | Education through smartphone app | Postpartum | 6 | Self-directed smartphone app | NA
Schwarz, 2024^199^; US | IG1 | Virtual educational session | Prenatal | 0.14 | 1 × 10 min virtual counseling session | NR
Sevda, 2023^200^ | IG1 | Breastfeeding education via WhatsApp with online support as needed | Peripartum, Postpartum | 26 | 16 × 2 min virtual sessions; + optional online support | NA
Simsek-Cetinkaya, 2024^201^; Turkey | IG1 | Educational workshop followed by web-based support | Prenatal, Postpartum | 24 | 1 × 120 min in-person sessions; + ongoing web-based support | Nurse
Stockdale, 2008^202^; Israel | IG1 | Group breastfeeding education | Prenatal, Postpartum | 11 | 1 × prenatal group session; + breastfeeding information booklet and CD-ROM; + postpartum support up to 3 weeks | Midwife
Su, 2007^203^; Singapore | IG1 | Professional in-person breastfeeding education | Peripartum | 2 | 1 × 30 min in-hospital lactation support session; 1 × 30 min postpartum clinic support session; + printed guides | Lactation care provider
Su, 2007^203^; Singapore | IG2 | Video-based breastfeeding education and printed materials | Prenatal | 0.14 | Prenatal video + printed guides; + optional 15 min prenatal session with lactation consultant | Lactation care provider
Uscher-Pines, 2020^205^; US | IG1 | App-based, individualized professional breastfeeding support | Peripartum, Postpartum | 12 | 12 weeks of unlimited, on-demand access to IBCLC telehealth support | Lactation care provider (IBCLC)
Wallace, 2006^206^; UK | IG1 | Professional “hands off” breastfeeding support and printed materials | Peripartum | 0.14 | 1 × 240 min training session for midwives on a “hands off” support protocol | Midwife
Wambach, 2011^207^; US | IG1 | Peer and professional in-person and telephone breastfeeding education and support | Prenatal, Peripartum, Postpartum | 8 | 2 × 90-120 min prenatal group sessions; 3 × prenatal phone calls; ≥1 × in-hospital session; ≤5 × postpartum phone calls; + electric breast pump; *Support person encouraged to attend | Peer counselor and lactation care provider (IBCLC)
Wen, 2020^209^; Australia | IG1 | Professional telephone breastfeeding support and printed educational materials | Prenatal, Postpartum | 52 | 6 × 30-60 min phone support calls | Nurse
Wen, 2020^209^; Australia | IG2 | App-based breastfeeding education and printed educational materials | Prenatal, Postpartum | 52 | 8 SMS over 4 weeks; 6 mailed intervention booklets across 4 weeks | NA
Wong, 2014^210^; Hong Kong | IG1 | Professional in-person breastfeeding support | Prenatal | 0.14 | 1 × 45 min prenatal support session | Nurse
Yesil, 2023^211^; Turkey | IG1 | Group hospital-based education and followup phone support | Peripartum, Postpartum | 12 | 2 × 45-60 minutes group education sessions; 2 × 15-30 minutes telephone support | Research staff
BREASTFEEDING SUPPORT PLUS OTHER INTERVENTIONS
Edwards, 2013^145^; US | IG1 | Professional comprehensive prenatal and maternal health home-visiting intervention | Prenatal, Peripartum, Postpartum | 30 | 10 × weekly prenatal home visits; In-hospital support; 12 × postpartum home visits; + optional postpartum phone support; + optional breast pump | Doula
Fiks, 2017^148^; US | IG1 | Web-based peer support intervention focused on childhood obesity prevention | Prenatal, Postpartum | 48 | Mothers participated in groups as frequently as they desired | Psychologist-led peer support
Gross, 2016^156^; US | IG1 | Family-centered group education focused on childhood obesity prevention | Prenatal, Peripartum, Postpartum | 36 | 2 × 45-60 min individual nutrition counseling sessions; 5 nutrition and parenting support groups | Registered dietitians with maternal-child health experience and trained as certified lactation counselors
Hans, 2018^157^; US | IG1 | Professional and peer comprehensive prenatal and maternal health home-visiting intervention | Prenatal, Peripartum, Postpartum | 16 | 15 × in-person sessions; 1 × in-hospital support during birth | Doula and peer counselor
Hoffmann, 2019^159^; Germany | IG1 | Professional in-person support focused on healthy weight gain during pregnancy | Prenatal, Postpartum | 36 | 4 × 30-45 min in-person sessions | Midwives, gynecologists or medical staff
Howell, 2014^161^; US | IG1 | Professional in-person and telephone support to reduce postpartum depressive symptoms | Peripartum, Postpartum | 2 | 1 × in-hospital education session; 1 × postpartum followup phone call | Social worker
Kenyon, 2016^165^; UK | IG1 | Peer, individualized case management to reduce postpartum depressive symptoms | Prenatal, Postpartum | 18 | NR | Pregnancy outreach worker
Laliberté, 2016^170^; Canada | IG1 | Comprehensive support intervention, including professional breastfeeding support | Postpartum | 6 | ~3 sessions^*^ | Lactation care provider, nurse, and physician
Lewkowitz, 2018^173^; US | IG1 | Peer home-visiting intervention focused on healthy weight gain during pregnancy | Prenatal | 26 | 13 × 60 min individual sessions | Peer counselor
Lutenbacher, 2022^177^; US | IG1 | Comprehensive intervention focused on providing services to families considered at-risk for poor health outcomes, including peer-based breastfeeding support | Prenatal, Postpartum | 74 | Monthly home (or remote) visits | Community health worker
Mottl-Santiago, 2023^184^; US | IG1 | Enhanced community doula support | Prenatal, Peripartum, Postpartum | 8 | Up to 8 × 2-hr prenatal home visits; Support through labor and delivery; Up to 4 × 2-hr postpartum home visits; + screening and legal intervention for social risks | Doula
Paul, 2012^189^; US | IG1 | Professional home-visiting postpartum intervention | Postpartum | 2 | 1 × postpartum home visit; 1 × postpartum clinic visit | Nurse
Quinlivan, 2003^192^; Australia | IG1 | Professional comprehensive prenatal and maternal health home-visiting intervention | Postpartum | 16 | 6 × 60-240 min postpartum home visits | Midwife
Taylor, 2017^204^; New Zealand | IG1 | Professional clinic- and home-based intervention focused on obesity prevention, including professional breastfeeding support | Prenatal, Postpartum | 19 | 8 total sessions, 3 focused on breastfeeding; 1x 30-min group session; 2 × 30-45 min individual sessions | Lactation care provider (IBCLC)
Wen, 2011^208^; Australia | IG1 | Professional home-visiting intervention focused on childhood obesity prevention | Prenatal, Postpartum | 62 | 1 × 60-120 min prenatal home visit; 5 × 60-120 min postpartum home visits | Nurse

Abbreviations: BF = breastfeeding; EHR = electronic health record; Hrs = hours; IBCLC = International Board-Certified Lactation Consultant; IG = intervention group; MI = motivational interviewing; min = minutes; NA = not applicable; NR = not reported; US = United States; WIC = Women, Infants and Children.

* Most women attended 3 or more clinic visits.

### Breastfeeding Education and Support

Most of the 90 included trials (75 trials with 83 unique intervention arms) provided interventions focused specifically on breastfeeding education and support. Most provided formal education and/or support given by a professional, such as nurses, midwives, physicians, and/or lactation care providers.^122,^ ^123,^ ^125,^ ^127–129,^ ^131–139,^ ^144,^ ^146,^ ^149,^ ^151–154,^ ^158,^ ^160,^ ^163,^ ^164,^ ^166–169,^ ^171,^ ^172,^ ^175,^ ^176,^ ^178–183,^ ^186–188,^ ^190,^ ^191,^ ^194–197,^ ^201–203,^ ^205,^ ^206,^ ^209–211^ Eight trials explicitly stated that the lactation care providers involved in the intervention were IBCLC or held some other lactation support certification.^131,^ ^132,^ ^137,^ ^138,^ ^183,^ ^188,^ ^194,^ ^205^ In 14 trials, breastfeeding support was provided by trained peers.^126,^ ^130,^ ^140–143,^ ^147,^ ^150,^ ^155,^ ^162,^ ^174,^ ^185,^ ^193,^ ^207^ In these cases, peer counselors were recruited specifically for the study: they were chosen to represent the sample population (e.g., adolescents, WIC recipients) and had previous breastfeeding experience. Two peer-led interventions also included support from an IBCLC lactation consultant.^174,^ ^207^

The timing, duration, and number of sessions of the interventions varied widely. Figure 4 illustrates the intervention timing and duration of each study. In just about half of the study groups (36 of 75 trials), the intervention occurred in just one time period, either during the prenatal period, during the hospital stay, or during the postpartum period, while interventions spanned across or in more than one time period (i.e., prenatal and peripartum; prenatal and postpartum) in the remaining just over half of studies. The total duration of interventions also varied widely and ranged from 1 day (1 session) to over a year of ongoing support. Eighteen intervention groups had interventions that were delivered in a single session, most occurring during the prenatal period (12/18) or during the hospital stay (5/18) and one during the postpartum period. Most interventions consisted of six or fewer sessions (median, 4; range, 1–20). Interventions that included seven or more sessions all included contact with participants during the postpartum period, with most also intervening during the prenatal and/or peripartum period as well.

Figure 4 Intervention Dose, According to Timing of Intervention

*Trial includes more than one active intervention group.

Note: Color indicates timing, which is also denoted in the first column.

A screen shot of a computer Description automatically generated

Most interventions were provided directly to women individually, but 12 interventions included group sessions with other mothers.^130,^ ^135,^ ^137,^ ^138,^ ^142,^ ^143,^ ^150,^ ^152,^ ^188,^ ^191,^ ^193,^ ^209^ Twelve interventions encouraged or required that a partner, coparent, or other support person also take part in the intervention. Twenty-eight of the interventions were provided completely remotely via telephone calls,^130,^ ^135,^ ^137,^ ^138,^ ^142,^ ^143,^ ^150,^ ^152,^ ^191,^ ^193,^ ^209^ a smartphone app,^124,^ ^134,^ ^147,^ ^172,^ ^176,^ ^183,^ ^197,^ ^198,^ ^205,^ ^209^ online,^126,^ ^133,^ ^140,^ ^144,^ ^152,^ ^154,^ ^162,^ ^166,^ ^174,^ ^175,^ ^179,^ ^180,^ ^185,^ ^199,^ ^200^ or using text messages.^129^ The remaining interventions all provided at least one in-person support session in the hospital, clinic, or at home. Fourteen interventions in 13 trials included home visits with or without additional clinic-based in-person support, telephone, or text-based support.^126,^ ^133,^ ^140,^ ^144,^ ^152,^ ^154,^ ^162,^ ^166,^ ^174,^ ^175,^ ^179,^ ^180,^ ^185^ Most home visits took place during the postpartum period, but some also included prenatal home visits.

Intervention content focused on general breastfeeding education, including the maternal and infant benefits of breastfeeding and the importance of exclusive breastfeeding; advice on proper latching and other techniques to reduce breastfeeding problems; and messages designed to increase breastfeeding self-efficacy. Most interventions also provided emotional and instrumental support, which often included hands-on support to assist with proper infant positioning.

Few studies mentioned provided material support to participants. One intervention provided an ergonomic infant carrier to women during a one-time prenatal home visit to facilitate increased physical contact from birth onward.^175^ The home-visiting team was trained to help participants with their carrier, and all participants had unlimited access to an instructional video; however, no further breastfeeding counseling was provided. Five additional trials noted providing intervention participants with nursing bras, breast pumps, or other material support.^131–133,^ ^140,^ ^174^ Six studies explicitly mentioned including information about expressing and/or storing breast milk.^133,^ ^139,^ ^152,^ ^154,^ ^172,^ ^190^

Only five studies noted cultural adaptations or considerations in the design or delivery of the intervention.^130,^ ^133,^ ^135,^ ^162,^ ^174^ Minimal information was provided on how interventions were culturally tailored beyond statements such as using a culturally appropriate lactation doll and nipple, addressing cultural issues previously found to influence initiation or continuation, and addressing cultural barriers and concerns.

### Breastfeeding Plus

Fifteen trials evaluated interventions that involved additional content and messages beyond breastfeeding support.^145,^ ^148,^ ^156,^ ^157,^ ^159,^ ^161,^ ^165,^ ^170,^ ^173,^ ^177,^ ^184,^ ^189,^ ^192,^ ^204,^ ^208^ In seven of these trials, five of which took place in the United States, women in the intervention groups received a comprehensive prenatal and/or postpartum home visiting program that included breastfeeding support in addition to general education and support for multiple aspects of maternal and infant well-being such as newborn care, contraception, infant vaccination schedules, and child development.^145,^ ^157,^ ^170,^ ^177,^ ^184,^ ^189,^ ^192^ In all cases, the interventions were led by community doulas, nurse midwives, or community health workers with or without additional peer counselors.

Eight studies targeted specific subgroups of women of specific ages, race or ethnicity, or socioeconomic status. Three studies were in low-income Black mothers,^145,^ ^148,^ ^172^ two in low-income Hispanic mothers,^156,^ ^177^ and three low-income Black or Hispanic mothers.^157,^ ^161,^ ^184^ Two trials were also limited to younger Black or Hispanic women (age <21 or <26 years)^145,^ ^157^ and an additional trial was limited to low-income adolescents (age <18 years).^192^

Two studies evaluated interventions designed to reduce postpartum depression. One trial in the United States included postpartum behavioral education among predominately low-income black and Hispanic or Latina women versus usual care;^161^ the other, in the United Kingdom, provided prenatal and postnatal support that included breastfeeding support, general postpartum advice and social support, and advice about infant care versus usual postpartum support.^165^

In two studies, interventions were designed to support healthy weight gain during pregnancy and reduce postpartum weight retention.^159,^ ^173^ In addition to including content with messages to support breastfeeding, lifestyle recommendations related to physical activity and healthy eating were also a part of the intervention.^159,^ ^173^ In these trials, most of the intervention components took place during pregnancy. One of the trials limited inclusion to low-income Black women in the United States who had overweight or obesity pre-pregnancy and compared a home-based parenting support and child developmental educational intervention with the same intervention plus content on breastfeeding.^173^ The other intervention in the Netherlands offered individual counseling on physical activity, nutrition, and weight monitoring, including messages about breastfeeding alongside and compared with standard prenatal care.^159^

Finally, four studies were framed as childhood obesity prevention interventions and focused on broad infant feeding practices, including breastfeeding.^148,^ ^156,^ ^204,^ ^208^ All three interventions started in the prenatal period and continued postpartum, for 9 to 12 months of intervention. One was a home-based prenatal and postpartum intervention provided by a nurse in Australia,^208^ one was a comprehensive food and activity counseling program provided in New Zealand,^204^ one involved prenatal and postpartum individual counseling with registered dietitians trained as lactation counselors alongside well-child visits and parenting support groups among low-income Hispanic and Latina women in the United States,^156^ and the remaining was a social media peer support group promoting healthy infant growth as well as maternal well-being among predominately low-income Black women living with obesity in the United States.^148^

### Control Groups

Almost all the studies included usual care control groups, although what constituted usual care was not fully described or was highly variable given the various settings, countries, and time frames in which the interventions took place. In all cases, mothers in both the intervention and control groups received usual care. The intervention components were either provided in addition to usual care services or replaced specific components of care (e.g., more intensive lactation support than routinely provided).

As part of usual care, many studies noted routine prenatal education, but the degree to which breastfeeding education was included in the prenatal education was rarely reported. Most studies described in-hospital (peripartum) and/or postpartum lactation support including print materials and hands-on breastfeeding assistance and education from maternity unit nursing staff, midwives, and/or lactation consultants or counselors. A few studies noted that breastfeeding support was also provided through “warm” telephone lines that mothers could call 24 hours a day for support and counseling. Ten of the studies explicitly mentioned that the studies took place in BFHI-accredited facilities.^126,^ ^129,^ ^140,^ ^149,^ ^167,^ ^172,^ ^174,^ ^179,^ ^202,^ ^211^ A few studies mentioned discharge materials routinely given to families, including videos or print materials on infant care and breastfeeding, manual breast pumps, lanolin cream, and a water bottle. Two studies explicitly stated that the hospital discharge bag included commercial milk formula.^135,^ ^160^

In the studies that recruited participants from WIC clinics, standard prenatal and/or postpartum maternity and infant services provided by local WIC clinics were provided; this is assumed to also vary by site, but generally included peer counselor-led breastfeeding support, access to a 24-hour telephone help hotline, home visits, and hands-on coaching. Many of the non-U.S. studies included routine postpartum home visits as part of usual care.^149,^ ^150,^ ^162,^ ^166,^ ^167,^ ^179,^ ^180,^ ^192,^ ^208^ A few studies mentioned providing information on peer support groups available in the community or other community resources.

Although we categorized the control groups in three studies as “no intervention,” it is very likely women in these groups also received usual maternity and breastfeeding support. In these cases, the interventions (providing an infant carrier^175^ or online/app-based support^148,^ ^176^) were compared with control groups who did not receive an infant carrier or access to the technology that supported the intervention. Finally, four studies utilized an attention control group where women in the control groups received the same intervention materials (e.g., videos, text messages) but the content focused on a topic other than breastfeeding (e.g., injury prevention, general infant health).^125,^ ^134,^ ^164,^ ^199^

## Quality of Included Evidence

We rated 28 of the 90 studies as good quality and the remaining 58 as fair quality (Table 4). In general, the limitations of the trials rated as fair quality included a lack of reporting details about randomization methods, including allocation concealment; small or unclear differences in baseline characteristics between intervention arms on variables that may relate to breastfeeding outcomes and were not accounted for in the analyses (such as intentions to breastfeed, parity, previous breastfeeding experience, marital status, employment); a lack of blinding of outcome assessors; attrition greater than 10 percent but less than 35 percent or differential attrition between study arms; and a lack of reporting on how missing data were handled. Additionally, while all studies relied on self-reported measures of breastfeeding and breastfeeding duration with or without verification from clinical records, the studies we rated as fair quality rarely noted the specific instruments, questions, or definitions used to measure breastfeeding, including whether the measure was based on a 24-hour recall or since birth. Studies that measured breastfeeding duration or time to weaning were especially prone to recall bias, and very few fair-quality studies described how observations were censored in the analyses.

## Summary of Results

A total of 19 studies (n=11,175) reported the effectiveness of breastfeeding support interventions on infant or maternal health outcomes (KQ 1). Ten trials (n=6,592) reported on infant health outcomes, which included gastrointestinal outcomes (k=2), otitis media (k=1), the number of healthcare visits for respiratory tract illnesses (k=1), and rates of general infant healthcare utilization, childhood illness, or minor infant health outcomes (k=8). Infant health outcomes were reported from the time of birth for up to 1 year in some studies. In general, the evidence was mixed, but in all cases, more favorable effects were seen on these outcomes among infants born to intervention versus control group parents. However, very few reported these differences to be statistically significantly different between groups. In cases where differences were seen in infant health outcomes, there were no apparent differences in rates of any or exclusive breastfeeding that seemed to be driving these effects. Furthermore, in some cases, the interventions included postpartum in-home nursing support, which could help protect against poor infant health outcomes, independent of its effect on breastfeeding.

For maternal health outcomes, nine trials (n=2,334) reported maternal symptoms of anxiety, depression, or well-being at up to 6 months postpartum. Most of the studies reported better symptom scores among intervention mothers versus control mothers; however, very few of the differences between groups were statistically different. In the two trials that reported maternal weight-related outcomes (n=2,533), no differences were seen between groups.

Breastfeeding outcomes (KQ 2) were reported as the prevalence of breastfeeding at various time points (k=89, n=49,597), continuous measures of the duration of breastfeeding (k=27, n=13,742), and the intensity of breastfeeding (k=6, n=1,977). In meta-analyses, there was a statistically significant association between participating in a breastfeeding support intervention and the prevalence of any and exclusive breastfeeding at less than 3 months, 3 months to less than 6 months, and 6 months (Table 8). For example, at 6 months, the likelihood of any breastfeeding and exclusive breastfeeding was 13 percent higher (RR, 1.13 [95% CI, 1.05 to 1.22]; I^2^=73.4; k=37; n=13,579) and 46 percent higher (RR, 1.46 [95% CI, 1.20 to 1.78]; I^2^=76.8; k=37; n=14,398), respectively. The median differences in absolute prevalence of breastfeeding between groups ranged from 1.3 to 7.1 percentage points at various time points for any and exclusive breastfeeding, with slightly larger effects for exclusive versus any breastfeeding. No effect was seen on the prevalence of breastfeeding initiation, but the absolute proportion of participants beginning to breastfeed in the first week of life was high among both intervention (median, 94.4%) and usual care groups (median, 90%), indicating a potential ceiling effect on outcomes. Eight trials reported the prevalence of any breastfeeding at 12 months, finding mixed results. There was no consistent evidence that the results varied by any prespecified population or intervention characteristics. In the subset of trials that reported continuous measures of time to stopping breastfeeding, all trials reported that infants born to persons in the intervention groups were breastfed longer than those in the control groups, although most did not report these differences to be statistically significantly different.

Table 6 Infant Health Outcomes

Author, Year | Group | Outcome | FU (wks) | IG N | CG N | IG (n/N, %) | CG (n/N, %) | Between-group value | Study-reported between group difference | Study-reported p-value
Anderson, 2005^126^ | IG1 | Infant GI Infection (1 or more diarrhea episodes) | 12 | 63 | 72 | 11/63 (17.5%) | 27/72 (37.5%) | RR (95% CI) | 2.15 (1.16 to 3.97) | NR
Bonuck, 2006^133^ | IG1 | Infant GI Infection (ED or outpatient visits for >1 GI illness) | 52 | 163 | 175 | 37/163 (22.7%) | 45/175 (25.7%) | NR | NR | NR
Bonuck, 2006^133^ | IG1 | Infant otitis media (ED or outpatient visits for >1 case of otitis media) | 52 | 163 | 175 | 71/163 (43.6%) | 96/175 (54.9%) | NR | NR | NR
Bonuck, 2006^133^ | IG1 | Infant RTI (ED or outpatient visits for >2 respiratory tract illnesses) | 52 | 163 | 175 | 125/163 (76.7%) | 146/175 (83.4%) | NR | NR | NR
Bunik, 2010^135^ | IG1 | Infant HC utilization (Sick visit) | 4 | 149 | 165 | 37/149 (25.0%) | 59/165 (36.0%) | T-Test | NR | 0.05
Chapman, 2013^140^ | IG1 | Infant HC utilization (Infant hospitalizations) | 12 | NR | NR | NR/NR (10.0%) | NR/NR (26.0%) | aOR (95% CI) | 0.24 (0.07 to 0.82) | 0.02
Chapman, 2013^140^ | IG1 | Infant HC utilization (Infant hospitalizations) | 26 | NR | NR | NR/NR (11.0%) | NR/NR (28.0%) | aOR (95% CI) | 0.24 (0.07 to 0.86) | 0.03
Gagnon, 2002^153^ | IG1 | Infant HC utilization (Number of hospital admissions) | 8 | 259 | 254 | 3/259 (1.2%)^*^ | 7/254 (2.8%)^†^ | NR | NR | NR
Hopkinson, 2009^160^ | IG1 | Infant HC utilization (Visited emergency room) | 4 | 225 | 240 | 20/225 (8.9%) | 22/240 (9.2%) | NR | NR | 0.951
Hopkinson, 2009^160^ | IG1 | Infant HC utilization (Visited pediatrician) | 4 | 225 | 240 | 172/225 (76.3%) | 197/240 (82.1%) | NR | NR | 0.127
Laliberte, 2016^170^ | IG1 | Infant HC utilization (total participants with at least one reported ED visit) | 12 | 307 | 145 | 63/307 (20.5%) | 26/145 (17.9) | OR (95% CI) | 1.02 (0.61 to 1.72) | NR
Laliberte, 2016^170^ | IG1 | Infant HC utilization (total participants with at least one reported infant readmission) | 12 | 307 | 145 | 20/307 (6.5%) | 9/145 (6.2%) | OR (95% CI) | 0.97 (0.42 to 2.20) | NR
Puharic, 2020^191^ | IG1 | Childhood Illness (“Childhood illness”) | 12 | 129 | 123 | 9/129 (7%) | 29/123 (24%) | NR | NR | NR
Puharic, 2020^191^ | IG1 | Childhood Illness (“Childhood illness”) | 24 | 129 | 123 | 9/129 (7%) | 16/123 (2%) | NR | NR | NR
Puharic, 2020^191^ | IG1 | Infant HC utilization (Sought medical assistance) | 12 | 9 | 29 | 8/9 (89%) | 28/29 (97%) | NR | NR | NR
Puharic, 2020^191^ | IG1 | Infant HC utilization (Sought medical assistance) | 24 | 9 | 11 | 7/9 (78%) | 11/11 (100%) | NR | NR | NR
Nilsson, 2017^186^ | IG1 | Infant HC utilization^‡^ | 1 | 2065 | 1476 | 43/2065 (2.2%) | 55/1476 (3.6%) | aOR (95% CI) | 0.55 (0.37 to 0.81) | <0.01
Nilsson, 2017^186^ | IG1 | Infant HC utilization^‡^ | 4 | 2065 | 1476 | 54/2065 (2.8%) | 40/1476 (2.5%) | aOR (95% CI) | 0.96 (0.58 to 1.59) | 0.89
Sari, 2020^196^ | IG1 | Minor infant health outcomes^§^ | 12 | NR | NR | NR/NR (NR%) | NR/NR (NR%) | NR | NR | NR^‖^

Abbreviations: aOR = adjusted OR, aRR = adjusted risk ratio; CG = control group; CI = confidence interval; ED = emergency department; FU = followup; GI = gastrointestinal; HC = healthcare; IG = intervention group; N = number; NR = not reported; RR = risk ratio; wks = weeks.

* 2 admissions for fever/viral episodes and 1 for whooping cough.

† 2 admissions for jaundice, 2 for fever/viral episodes, 1 for cord infection, 1 for ear infection, and 1 for lethargy.

‡ Readmission of the infant within 7-28 days postnatally due to jaundice, dehydration, excessive weight loss, and nutritional problems.

§ Identified problems: eye, nasal obstruction, skin lesion, rash, umbilicus, moniliasis, jaundice, inguinal hernia, colic, hiccup, constipation, diarrhea, gas problems.

‖ The most common health problem for the infants in both groups was gas that increased in the first month. However, this rate was lower in the intervention group (31.4% in first month; 14.3% in third month) compared with the control group (44.4% in first month; 33.3% in third month). At the end of the first postnatal month, the incidence of rash, moniliasis, colic, and constipation was lower in the intervention compared with the control group.

Table 7 Maternal Health Outcomes

Author, Year | Group | Outcome | FU (wks) | IG N | CG N | Within-group value | IG | CG | Study-reported between group value | Study-reported between-group difference | Study-reported p-value
Bender, 2022^129^ | IG1 | Depressive Symptoms (PHQ-2, Scale) | 2 | NR | NR | Median (IQR) | 2 (0 to 4) | 2 (0 to 4) | NR | NR | 0.77
Bender, 2022^129^ | IG1 | Depressive Symptoms (PHQ-2, Scale) | 6 | NR | NR | Median (IQR) | 2 (1 to 3) | 2.5 (1.5 to 3.5) | NR | NR | 0.33
Clarke, 2020^141^ | IG1 | Maternal wellbeing (Warwick-Edinburgh Mental Well-Being Scale) | 8 | 40 | 44 | Mean (95% CI) | −2.5 (−4.6 to −0.5) | −0.1 (−3.1 to 3.0) | NR | NR | NR
Clarke, 2020^141^ | IG1 | Maternal wellbeing (Warwick-Edinburgh Mental Well-Being Scale) | 24 | 39 | 44 | Mean (95% CI) | −2.9 (−4.8 to −1.0) | −0.2 (−2.8 to 2.4) | NR | NR | NR
Franco-Antonio, 2020^151^ | IG1 | Depressive Symptoms (EPDS, Scale) | 12 | 42 | 40 | Median (IQR) | 5.5 (1.75 to 9) | 8 (6 to 11) | NR | NR | 0.023
Franco-Antonio, 2020^151^ | IG1 | Depression (EPDS, Score ≥10) | 12 | 42 | 40 | n/N (%) | 5/42 (11.9%) | 13/40 (32.5%) | aOR (IQR) | 0.33 (0.10 to 1.08) | 0.068
Gagnon, 2002^153^ | IG1 | Anxiety Symptoms (State-Trait Anxiety Inventory, Scale) | 2 | 259 | 253 | Mean (SD) | 28.7 (7.9) | 28.4 (8.0) | Mean Difference (Range) | 0.3 (−0.5 to 1.1) | NR
Hans, 2018^157^ | IG1^*^ | Depressive Symptoms (CES-D, Score ≥16) | 3 | 140 | 142 | n/N (%) | 31/140 (22.1%) | 31/142 (21.8%) | aOR (95% CI) | 0.96 (0.53 to 1.71) | >0.05
Hans, 2018^157^ | IG1^*^ | Depressive Symptoms (CES-D, Score ≥16) | 12 | 138 | 139 | n/N (%) | 18/138 (13.0%) | 21/139 (15.1%) | aOR (95% CI) | 0.95 (0.47 to 1.91) | 0.45
Kenyon, 2016^165^ | IG1^†^ | Depressive Symptoms (EPDS, Scale) | 12 | 489 | 519 | Mean (SE) | 6.76 (0.23) | 7.35 (0.24) | MD (95% CI) | −0.59 (−1.24 to 0.06) | 0.08
Kenyon, 2016^165^ | IG1^†^ | Depression (EPDS, Score ≥13) | 12 | 489 | 519 | n/N (%) | 61/489 (12%) | 87/519 (17%) | aRR (95% CI) | 0.74 (0.55 to 1.01) | 0.05
Hoffmann, 2019^159^ | IG1^‡^ | Weight loss (kg) | 8 | 970 | 929 | Mean (SD) | 9.9 (3.4) | 9.7 (3.4) | aMD (95% CI) | 0.11 (−0.22 to 0.44) | 0.500
Hoffmann, 2019^159^ | IG1^‡^ | Weight loss (kg) | 52 | 841 | 828 | Mean (SD) | 14.3 (5.9) | 13.4 (6.0) | aMD (95% CI) | 0.85 (0.22 to 1.49) | 0.008
Hoffmann, 2019^159^ | IG1^‡^ | Weight loss (kg) | 8 | 49 | 41 | Mean (SD) | 81.0 (18.6) | 79.7 (20.1) | Cohen’s d | 0.07 | NR
Hoffmann, 2019^159^ | IG1^‡^ | Weight loss (kg) | 26 | 49 | 41 | Mean (SD) | 76.3 (18.9) | 79.0 (17.1) | Cohen’s d | −0.14 | NR
Hoffmann, 2019^159^ | IG1^‡^ | Weight loss (kg) | 36 | 48 | 41 | Mean (SD) | 72.8 (18.1) | 80.2 (9.6) | Cohen’s d | −0.41 | NR
Hoffmann, 2019^159^ | IG1^‡^ | Weight loss (kg) | 52 | 49 | 41 | Mean (SD) | 69.0 (15.4) | 79.2 (10.0) | Cohen’s d | −0.66 | NR
Hoffmann, 2019^159^ | IG1^‡^ | Weight loss (kg) | 60 | 49 | 41 | Mean (SD) | 59.9 (15.2) | 78.1 (11.9) | Cohen’s d | −1.19 | 0.001^‖^
Lutenbacher, 2022^177^ | IG1 | Depressive Symptoms (EPDS, Scale) | 0^§^ | 51 | 51 | Median (IQR) | (0 to 5) | 2.0 (0 to 5) | Cohen’s d | −0.06 | NR
Lutenbacher, 2022^177^ | IG1 | Depressive Symptoms (EPDS, Scale) | 2 | 56 | 53 | Median (IQR) | 0.0 (0 to 2) | 0.0 (0 to 2) | Cohen’s d | −0.01 | NR
Lutenbacher, 2022^177^ | IG1 | Depressive Symptoms (EPDS, Scale) | 8 | 57 | 53 | Median (IQR) | 0.0 (0 to 2) | 0.0 (0 to 2) | Cohen’s d | 0.02 | NR
Lutenbacher, 2022^177^ | IG1 | Depressive Symptoms (EPDS, Scale) | 26 | 57 | 53 | Median (IQR) | 0.0 (0 to 2) | 0.0 (0 to 2) | Cohen’s d | 0.13 | NR
Lutenbacher, 2022^177^ | IG1 | Depressive Symptoms (EPDS, Scale) | 36 | 56 | 53 | Median (IQR) | 0.0 (0 to 2) | 0.0 (0 to 5) | Cohen’s d | −0.56 | NR
Lutenbacher, 2022^177^ | IG1 | Depressive Symptoms (EPDS, Scale) | 52 | 57 | 53 | Median (IQR) | 0.0 (0 to 0) | 1.0 (0 to 4) | Cohen’s d | −0.79 | NR
Lutenbacher, 2022^177^ | IG1 | Depressive Symptoms (EPDS, Scale) | 60 | 57 | 53 | Median (IQR) | 0.0 (0 to 0) | 1.0 (0 to 4) | Cohen’s d | −0.67 | <0.001^‖^
Lutenbacher, 2022^177^ | IG1 | Parental Stress (PSI-SF, Score) | 0^§^ | 49 | 41 | Mean (SD) | 85.1 (20.1) | 85.7 (20.7) | Cohen’s d | NR | 0.823
Lutenbacher, 2022^177^ | IG1 | Parental Stress (PSI-SF, Score) | 2 | 48 | 41 | Mean (SD) | 78.0 (22.1) | 83.0 (19.8) | Cohen’s d | −0.223 | NR
Lutenbacher, 2022^177^ | IG1 | Parental Stress (PSI-SF, Score) | 8 | 49 | 41 | Mean (SD) | 81.0 (18.6) | 79.7 (20.1) | Cohen’s d | 0.07 | NR
Lutenbacher, 2022^177^ | IG1 | Parental Stress (PSI-SF, Score) | 26 | 49 | 41 | Mean (SD) | 76.3 (18.9) | 79.0 (17.1) | Cohen’s d | −0.14 | NR
Lutenbacher, 2022^177^ | IG1 | Parental Stress (PSI-SF, Score) | 36 | 48 | 41 | Mean (SD) | 72.8 (18.1) | 80.2 (9.6) | Cohen’s d | −0.41 | NR
Lutenbacher, 2022^177^ | IG1 | Parental Stress (PSI-SF, Score) | 52 | 49 | 41 | Mean (SD) | 69.0 (15.4) | 79.2 (10.0) | Cohen’s d | −0.66 | NR
Lutenbacher, 2022^177^ | IG1 | Parental Stress (PSI-SF, Score) | 60 | 49 | 41 | Mean (SD) | 59.9 (15.2) | 78.1 (11.9) | Cohen’s d | −1.19 | 0.001^‖^
Puharic, 2020^191^ | IG1 | BMI (kg/m^2^) | 12 | 129 | 123 | Median (IQR) | 23.2 (21.8 to 25.3) | 24.0 (21.4 to 26.5) | NR | NR | 0.933
Puharic, 2020^191^ | IG1 | BMI (kg/m^2^) | 24 | 129 | 123 | Median (IQR) | 22.3 (20.9 to 24.4) | 23.3 (20.9 to 25.7) | NR | NR | 0.551
Sari Ozturk, 2023^197^ | IG1 | Anxiety Symptoms (State-Trait Anxiety Inventory, Scale) | 0^¶^ | 33 | 33 | Mean (SD) | 44.7 (1.3) | 50.3 (2.1) | NR | NR | 0.04
Sari Ozturk, 2023^197^ | IG1 | Anxiety Symptoms (State-Trait Anxiety Inventory, Scale) | 8 | 33 | 33 | Mean (SD) | 45.7 (0.9) | 55.8 (2.1) | NR | NR | 0.00
Simsek-Cetinkaya, 2024^201^ | IG1 | Depressive Symptoms (EPDS, Scale) | 1 | 36 | 36 | Mean (SD) | 8.5 (1.1) | 8.6 (1.1) | NR | NR | 0.678
Simsek-Cetinkaya, 2024^201^ | IG1 | Depressive Symptoms (EPDS, Scale) | 12 | 36 | 36 | Mean (SD) | 6.9 (3.3) | 8.1 (1.0) | NR | NR | 0.038
Simsek-Cetinkaya, 2024^201^ | IG1 | Depressive Symptoms (EPDS, Scale) | 24 | 36 | 36 | Mean (SD) | 6.0 (2.7) | 7.5 (3.6) | NR | NR | 0.042

Abbreviations: aMD = adjusted mean difference; aOR = adjusted odds ratio; aRR = adjusted risk ratio; BMI = body mass index; CES-D = Center for Epidemiological Studies Depression Scale; CG = control group; CI = confidence interval; EPDS = Edinburgh Postnatal Depression Scale; FU = followup; IG = intervention group; IQR = interquartile range; kg = kilograms; m = meters; MD = mean difference; N = number; NR = not reported; PHQ-2 = Patient Health Questionnaire 2; PSI = Parenting Stress Index-Short Form; SD = standard deviation; SE = standard error; wks = weeks.

* Comprehensive prenatal/postpartum intervention, including professional breastfeeding support.

† Intervention to reduce postpartum depressive symptoms, including professional or peer breastfeeding support.

‡ Intervention to support healthy weight gain during pregnancy, including professional breastfeeding support.

§ Prenatal.

‖ Interaction effect in mixed-effects general linear model controlling for baseline score.

¶ 32–33 weeks of pregnancy.

Table 8 Summary of Pooled Results for Any and Exclusive Breastfeeding

Time Point | Breastfeeding Outcome | K (new) | N Analyzed | RR (95% CI) | I^2^, % | Absolute Risk Difference, Median (IQR)
Initiation^*^ | Any | 37 (19) | 15,006 | 1.01 (1.00, 1.02) | 13.2 | 1.45 (0 to 5.1)
Initiation^*^ | Exclusive | 27 (18) | 10,622 | 1.16 (1.05, 1.29) | 75.6 | 5.3 (−0.2 to 18.25)
<3 months | Any | 47 (18) | 15,663 | 1.06 (1.03, 1.08) | 55.1 | 5.2 (1.5 to 9.8)
<3 months | Exclusive | 51 (29) | 17,431 | 1.21 (1.14, 1.28) | 36.6 | 7.1 (3.0 to 22.0)
3 to <6 months | Any | 40 (14) | 17,580 | 1.09 (1.04, 1.12) | 42.6 | 4.1 (−2.6 to 9.95)
3 to <6 months | Exclusive | 40 (22) | 11,032 | 1.31 (1.17, 1.46) | 66.6 | 5.8 (0.35 to 14.95)
6 months | Any | 37 (16) | 13,579 | 1.13 (1.05, 1.22) | 73.4 | 6.0 (−2.1 to 10.8)
6 months | Exclusive | 37 (20) | 14,398 | 1.46 (1.20, 1.78) | 76.8 | 3.2 (0.9 to 8.7)
12 months | Any | 8 (4) | 4,607 | 1.04 (0.91, 1.18) | 0.0 | 1.3 (−1.4 to 6.1)

* From birth to 1 week postpartum.

Abbreviations: BF = breastfeeding; CI = confidence interval; IQR = interquartile range; K = number of studies; N = number (of persons); RR = risk ratio.

Potential harms related to breastfeeding support interventions (KQ 3) were minimally reported (k=7, n=1,404) and indicated no harm related to the interventions. Additionally, there was no evidence of differences in the prevalence of breastfeeding “problems” between those in the intervention versus usual care groups.

## Detailed Results

### KQ 1 Do Interventions to Support Breastfeeding Improve Child and Maternal Health Outcomes?

Eighteen of the 90 included studies (n=10,505) reported a measure of infant or maternal health.^126,^ ^129,^ ^133,^ ^135,^ ^140,^ ^141,^ ^151,^ ^153,^ ^157,^ ^159,^ ^160,^ ^165,^ ^170,^ ^177,^ ^186,^ ^191,^ ^196,^ ^197,^ ^201^ Detailed results for infant health outcomes are in Table 6 and for maternal health outcomes in Table 7.

#### Infant Health Outcomes

Two studies of fair quality reported on infant gastrointestinal outcomes, with conflicting results.^126,^ ^133^ Anderson and colleagues (n=135) reported that the risk of infants experiencing one or more diarrheal episodes during the first 3 months of life was more than twofold higher in the usual care group (37.5%) than in a peer counseling intervention group (17.5%) (RR, 2.15 [95% CI, 1.16 to 3.97]); this study also found lower prevalence of exclusive breastfeeding at both 2 and 3 months in the control group compared with the intervention group.^126^ Bonuck and colleagues (2006) (n=338), however, reported no significant differences in the proportion of emergency or outpatient visits for gastrointestinal illnesses in infants of women who attended a prenatal and postpartum support intervention (22.7%) and in infants in the usual care group (25.7%) at 1 year. In this study, mothers in the intervention group breastfed for a statistically significantly longer duration than the women in the control group, but there were no differences in the proportion of women who exclusively breastfed at any time point.^133,^ ^213^

Bonuck and colleagues (2006) also reported infant outcomes for otitis media and respiratory tract illnesses for up to 1 year.^133^ In the full sample, there were no statistically significant differences in the percent of otitis media cases (43.6% vs. 54.9%) or the number of healthcare visits for respiratory tract illnesses (76.7% vs. 83.4%) for intervention versus control participants. In preplanned analyses, infants in the usual care group who were not Medicaid recipients had significantly more cases of otitis media than infants in the intervention group (p ≤0.03); there was no difference among infants who were Medicaid recipients.

Eight studies reported outcomes of infant healthcare utilization,^135,^ ^140,^ ^153,^ ^160,^ ^170,^ ^186,^ ^191^ childhood illness,^191^ or minor infant health outcomes^196^ at 4 weeks to 6 months of followup. There was a general trend of lower rates of healthcare visits and hospital admissions among infants in the intervention group compared with control groups, although these differences were not statistically significantly different between groups in all studies. For instance, despite finding a statistically significantly higher prevalence of exclusive breastfeeding at 4 weeks between groups, Hopkinson and colleagues found no significant difference in the number of infant visits to the pediatrician or emergency room at 4 weeks postpartum between women randomized to a lactation care provider-led postpartum breastfeeding support intervention (76.3% visited pediatrician, 8.9% visited emergency room; n=225) and those receiving usual care (82.1% visited pediatrician, 9.2% visited emergency room; n=240).^160^ Bunik reported that infants born to mothers assigned to a nurse-delivered brief telephone postpartum support intervention were less likely to have a sick visit by 4 weeks postpartum than were infants born to mothers in the usual care group (25% vs. 36%, respectively; p=0.05); however, there were no significant differences between treatment groups with respect to well-baby and sick care visits at 3 and 6 months postpartum or between any or exclusive breastfeeding at 1, 3, and 6 months.^135^

Gagnon observed that infant hospital admission for multiple conditions (including fever/viral episodes, jaundice, ear infection, and lethargy) during the first 8 weeks postpartum was more than twofold higher in the usual care group (7/254 [2.8%]) than in the intervention group receiving a postpartum in-home nursing visit and optional phone support (3/259 [1.2%]); however, there was no significant difference in the prevalence of any breastfeeding between groups at 2 weeks.^153^ Nilsson and colleagues found a statistically significantly lower likelihood of readmission of the infant within 7 days (adjusted odds ratio [aOR], 0.55 [95% CI, 0.37 to 0.81]) but not from 7 to 28 days (aOR, 0.96 [95% CI, 0.58 to 1.59]) due to jaundice, dehydration, excessive weight loss, and nutritional problems among infants born to women in the intervention versus control group.^186^ Chapman and colleagues reported that infants of mothers who received a breastfeeding peer counseling intervention were significantly less likely to be hospitalized during the first 3 to 6 months after birth after adjustment for maternal age, delivery mode, infant birth weight, previous breastfeeding experience, maternal pregnancy BMI, and infant sex (6-month adjusted odds ratio [aOR], 0.24 [95% CI, 0.01 to 0.86]). There were no statistically significant differences, however, in the prevalence of otitis media, diarrhea, or emergency department visits between groups at 3 or 6 months. This study also did not find an effect on prevalence of any or exclusive breastfeeding beyond 2 weeks.^140^ Finally, in the studies by Puharicthe^191^ and Sari,^196^ both found statistically significantly greater prevalence of exclusive breastfeeding and lower rates of seeking medical assistance, childhood illness, and minor health outcomes at 3 to 6 months among infants in the intervention versus control groups, although these measures were variably defined and included gas, nasal obstructions, and skin lesion problems. Laliberte found no differences in the number of infants with at least one reported emergency room visit or infant readmission to the hospital, nor differences in the prevalence of exclusive breastfeeding at 12 weeks of followup.^170^

#### Maternal Health Outcomes

Eleven studies (n=5,441) reported on an outcome related to maternal well-being^129,^ ^141,^ ^153,^ ^157,^ ^165,^ ^177,^ ^197,^ ^201,^ ^218^ or maternal weight.^129,^ ^141,^ ^153,^ ^157,^ ^165,^ ^177,^ ^197,^ ^218^ In terms of maternal well-being outcomes (k=9, n=2,334), most studies reported no statistically significant differences between intervention versus control group women in symptoms of anxiety, depression, or well-being at up to 3 months postpartum using measures such as the Edinburgh Postnatal Depression Scale (EPDS), the Warwick-Edinburgh Mental Well-being Scale, or the State-Trait Anxiety Inventory.^129,^ ^141,^ ^153,^ ^157,^ ^165,^ ^177,^ ^197,^ ^201,^ ^218^ For example, in one study comparing an intervention consisting of a pregnancy outreach worker versus standard maternity care among disadvantaged families in the United Kingdom, no differences were seen in the mean EPDS score for all of the women recruited (mean difference [MD], −0.59 [95% CI, 1.24 to 0.06]). The same study found no differences in the proportion of women breastfeeding at 6 to 8 weeks.^165^ In one study comparing a prenatal and postpartum face-to-face, telephone, and text messaging breastfeeding support intervention versus usual care, symptoms appeared to worsen to a greater extent among intervention women than among control group women, although the direction of change within groups was not clearly reported in the study.^141^ In another study (n=82), a brief motivational intervention to increase breastfeeding was associated with a lower score on the EPDS at 3 months postpartum compared with the control group and was mediated by the effect of the intervention on the duration of breastfeeding.^218^ Furthermore, women in the intervention group (11.9%) were less likely to score above 10 on the EPDS than women in the control group (30%), although the relative risk was not statistically significant (aOR, 0.33 [95% CI, 0.10 to 1.08]; p=0.068).^218^ In one instance, a statistically significant interaction was found where an increasingly stronger effect of the community health worker home-visiting postpartum intervention was found on maternal depressive symptoms and parental stress over 15 months of followup compared with an educational control group. Similar statistically significant differences were found in rates of breastfeeding at 9, 12, and 15 months of followup.^177^ An additional recent trial (n=66) found statistically significantly lower state anxiety mean scores among women in the intervention (45.7) versus control groups (55.8) at 2 months following an art-based technology-supported breastfeeding intervention.^197^ Another study found statistically significant lower EPDS scores among intervention versus control participants at 3 and 6 months postpartum.^201^

Finally, two studies reported on maternal weight-related outcomes following the intervention (k=2, n=2,533).^159,^ ^191^ In the “Gesund leben in der Schwarngerschaft” (“healthy living in pregnancy,” GeliS) trial in Germany, pregnant women (n=71) in their third trimester were recruited and randomized to a comprehensive lifestyle intervention targeting adequate gestational weight gain or usual antenatal care. Intervention messages included information on healthy dietary and physical activity behavior during pregnancy, emphasis on monitoring gestational weight, and the importance of breastfeeding. Alongside usual care, the intervention was offered during three prenatal and one postpartum face-to-face counseling sessions. No differences were seen between groups in terms of excessive gestational weight gain and postpartum weight retention at 12 months,^159^ although there was a slightly higher prevalence of exclusive breastfeeding among intervention (87.4%) versus control group women (84.4%) (adjusted p-value <0.001).^159^ Similarly, in the study by Puharic (n=252), there was no difference in change in BMI from before pregnancy to 3 months postpartum between women receiving telephone breastfeeding support (median, 21.5 to 23.2) versus general pregnancy support (median, 21.6 to 24.0).^191^ The latter study did not focus on maternal weight gain or retention.

### KQ 2 Do Interventions to Support Breastfeeding Improve the Initiation, Duration, Intensity, and Exclusivity of Breastfeeding?

All but one^201^ of the 90 included trials (N=49,597) reported the effects of an intervention on at least one measure of breastfeeding, including the prevalence or proportion of persons reporting any or exclusive breastfeeding at a given point in time, a continuous measure of the duration of any or exclusive breastfeeding, or the intensity of breastfeeding at a given point in time.

#### Prevalence of Any and Exclusive Breastfeeding

As stated in our methods, we report the results on the prevalence of breastfeeding at five distinct time points: initiation (from birth to up to 1 week postpartum), less than 3 months (2 to 11 weeks postpartum), 3 months to less than 6 months (12 to 23 weeks), 6 months (24–26 weeks), and 12 months (48–52 weeks). Many trials contributed data to more than one time point. For outcomes related to any breastfeeding, proportions reflect the percentage of women who report breastfeeding at that given time point regardless of other supplementation, whereas for exclusive breastfeeding, the proportions reflect the percentage of women who report that their infant is exclusively receiving only breast milk. Thus, women who report exclusive breastfeeding are also included in the measure of any breastfeeding.

A summary of all the pooled results of our meta-analyses can be found in Table 8. Given that there were no differences between the effects of the breastfeeding only interventions versus the breastfeeding plus interventions for any outcome, the pooled results incorporate both sets of studies. Detailed results for the prevalence of breastfeeding for all timepoints by study can be found in Appendix E Table 2.

#### Breastfeeding Initiation

Forty-five trials reported the effects of an intervention on the prevalence of any and/or exclusive breastfeeding initiation. Initiation was defined variably, including generically as “initiation,” within an hour of birth, immediately after birth, up to 2 to 3 days after birth, and up to 7 days after birth. All the interventions had a prenatal component or contact shortly after delivery that was intended to increase the proportion of women starting to breastfeed compared with usual care.

##### Any Breastfeeding

Meta-analysis of 37 studies (n=15,006) found no statistically significant association with receiving a breastfeeding support intervention and any breastfeeding initiation, compared with usual care (RR, 1.01 [95% CI, 1.00 to 1.02]; I^2^=13.2%) (Figure 5). The absolute prevalence of any breastfeeding initiation varied from 49.1 percent to 100 percent across all groups, although in most studies that reported it, more than two-thirds of women in both the intervention and control groups started breastfeeding. The median absolute risk difference (ARD) and interquartile range (IQR) was 1.5 percentage points between groups (0 to 5.1). Despite most trials generally showing higher prevalence of breastfeeding initiation among mothers receiving the intervention compared with mothers receiving usual care, only five of the individual trials found a statistically significant benefit.^126,^ ^131,^ ^132,^ ^145,^ ^207^

Figure 5 Any Breastfeeding Initiation Pooled Analysis

Abbreviations: AUS = Australia; CAN = Canada; CG = control group; CI = confidence interval; DNK = Denmark; GBR = Great Britain; HKG = Hong Kong; IG = intervention group; N = number (of participants); NLD = Netherlands; RR = risk ratio; SGP = Singapore; US = United States.

The relatively high control group initiation rates and the small overall benefit suggested by the pooled results are consistent with ceiling effects for breastfeeding initiation. In trials that reported it, most reported that 80 percent or more of enrolled women intended to initiate breastfeeding (range, 52% to 100%).

##### Exclusive Breastfeeding

Fewer studies reported the prevalence of exclusive breastfeeding initiation; in those that did, the proportion of women who initiated exclusive breastfeeding ranged from 26.9 percent^203^ to 100 percent^163^ of women in the intervention compared to a range of 18.1 percent^203^ to 92.0 percent^163^ in usual care groups (median ARD, 5.3 [IQR, −0.2 to 18.3]). In pooled analyses (k=27, n=10,622), there was a greater likelihood of initiating exclusive breastfeeding among intervention versus control group women (RR, 1.16 [95% CI, 1.05 to 1.29 (Figure 6), although there was high statistical heterogeneity (I^2^=75.6%).

Figure 6 Exclusive Breastfeeding Initiation Pooled Analysis

Abbreviations: AUS = Australia; CAN = Canada; CG = control group; CI = confidence interval; DNK = Denmark; ESP = Spain; FRA = France; GBR = Great Britain; HKG = Hong Kong; IG = intervention group; IRL = Ireland; ISR = Israel; ITA = Italy; N = number (of participants); NLD = Netherlands; RR = risk ratio; SGP = Singapore; TUR = Turkey; US = United States.

Visual examination of the funnel plot for exclusive breastfeeding initiation revealed asymmetric patterns and the results of the Peters’ test for small study effects was statistically significant (p=0.0000), so we cannot exclude potential publication bias. A sensitivity analysis excluding the seven studies that had total sample sizes of less than 100^136,^ ^151,^ ^174,^ ^194,^ ^196,^ ^197,^ ^211^ resulted in an attenuated effect with greater precision while reducing statistical heterogeneity (RR, 1.05 [95% CI, 1.00 to 1.10]; I^2^=6.6%; k=16). Five of the seven smaller studies were all conducted in Turkey, and all reported much larger relative effects than the other studies.^136,^ ^194,^ ^196,^ ^197,^ ^211^ Thus, the effect size for exclusive breastfeeding initiation when all studies are pooled may be slightly overestimated due to small study effects, including potential publication bias.

#### Breastfeeding for Less Than 3 Months

There was a beneficial association between breastfeeding support interventions and the prevalence of both any and exclusive breastfeeding at less than 3 months (i.e., with breastfeeding reported at 2 to 11 weeks).

##### Any Breastfeeding

Meta-analysis combining the 47 trials (n=15,663) that reported the prevalence of any breastfeeding for less than 3 months found a statistically significant favorable association with breastfeeding support interventions versus control groups (RR, 1.06 [95% CI, 1.03 to 1.08]; I^2^=55.1%) (Figure 7). The prevalence of any breastfeeding was generally high, with most studies reporting more than 70 percent of intervention group women and more than 60 percent of control group women still breastfeeding between 2 and 8 weeks. The median ARD (IQR) in percentage points between groups was 5.2 (1.5 to 9.8).

Figure 7 Any Breastfeeding at Less Than 3 Months Pooled Analysis

Abbreviations: AUS = Australia; CAN = Canada; CG = control group; CI = confidence interval; DNK = Denmark; FRA = France; GBR = Great Britain; HKG = Hong Kong; IG = intervention group; ISR = Israel; N = number (of participants); NLD = Netherlands; RR = risk ratio; SGP = Singapore; US = United States.

##### Exclusive Breastfeeding

The pooled effect for exclusive breastfeeding at less than 3 months was more pronounced than that seen for any breastfeeding (RR, 1.21 [95% CI, 1.14 to 1.28]; k=51; n=17,431; I^2^=36.6%) in favor of the intervention groups (Figure 8). The absolute prevalence of exclusive breastfeeding at 2 to 8 weeks was highly variable, ranging from 6.7 percent among a sample of women in Australia^209^ to 96.1 percent among a sample of women in Spain^163^ in the intervention groups, with the median absolute difference between groups of 7.1 percentage points (IQR, 3 to 22 percentage points). There did not appear to be any pattern in the absolute prevalence of breastfeeding according to the precise weeks of followup (i.e., whether the measure was at 2 weeks vs. 8 weeks).

Figure 8 Exclusive Breastfeeding at Less Than 3 Months Pooled Analysis

Abbreviations: AUS = Australia; CAN = Canada; CG = control group; CI = confidence interval; DNK = Denmark; ESP = Spain; FRA = France; GBR = Great Britain; HKG = Hong Kong; IG = intervention group; IRL = Ireland; ISR = Israel; ITA = Italy; N = number (of participants); NLD = Netherlands; RR = risk ratio; SGP = Singapore; TUR = Turkey; US = United States.

#### Breastfeeding at 3 Months to Less Than 6 Months

A consistent beneficial effect of the interventions was seen on the prevalence of any and exclusive breastfeeding at 3 months to less than 6 months. There was slightly less consistency and precision in the pooled risk ratios, however, reflecting greater variability between groups among the trials.

##### Any Breastfeeding

Pooled analysis of 40 trials (n=17,580) found that participation in the intervention was associated with a 9 percent higher likelihood of still breastfeeding at 3 months to up to 6 months compared with usual care alone (RR, 1.09 [95% CI, 1.04 to 1.12]; I^2^=42.6%) (Figure 9). Among these trials, the prevalence of any breastfeeding during this timepoint ranged from 8.3^145^ to 100 percent^197^ (median, 56.2%) in the intervention groups. In the control groups, the range of any breastfeeding was 4.4^145^ to 94.6 percent^123^ (median, 50.0). The median absolute difference between groups was 4.1 percentage points (IQR, −2.6 percentage points [in favor of the control group] to 10.0 percentage points).

Figure 9 Any Breastfeeding at 3 Months to Less Than 6 Months Pooled Analysis

Abbreviations: AUS = Australia; CAN = Canada; CG = control group; CI = confidence interval; DNK = Denmark; FRA = France; GBR = Great Britain; HKG = Hong Kong; HRV = Croatia; IG = intervention group; ISR = Israel; N = number (of participants); NLD = Netherlands; RR = risk ratio; SGP = Singapore; US = United States.

##### Exclusive Breastfeeding

Meta-analysis combining 40 trials (n=11,032) that reported exclusive breastfeeding found a statistically significant benefit during this time period (RR, 1.31 [95% CI, 1.17 to 1.46]; I^2^=66.6%) (Figure 10). The median absolute difference between groups was slightly higher for exclusive breastfeeding at 5.8 percentage points between groups (IQR, 0 to 15.0 points).

Figure 10 Exclusive Breastfeeding at 3 Months to Less Than 6 Months Pooled Analysis

Abbreviations: AUS = Australia; CAN = Canada; CG = control group; CI = confidence interval; ESP = Spain; FRA = France; GBR = Great Britain; HKG = Hong Kong; IG = intervention group; IRL = Ireland; ISR = Israel; ITA = Italy; N = number (of participants); NLD = Netherlands; RR = risk ratio; SGP = Singapore; TUR = Turkey; US = United States.

One study^137^ (n=226) could not be included in any meta-analyses due to limited reporting of crude events; however, as reported by the authors, the intervention resulted in statistically significantly higher odds of exclusive breastfeeding at 1, 2, 4, and 12 weeks after birth after adjustment for pre-pregnancy BMI, gestational weight gain, parity, birth weight, gestational age, and infant sex (Appendix E Table 2). For instance, at 4 weeks, authors found the odds of exclusive breastfeeding to be 3 times higher among women receiving postpartum telephone support than among women in the control group (aOR, 2.99 [95% CI, 1.61 to 5.50]).^137^

#### Breastfeeding at 6 Months

Less than half of the trials reported the prevalence of any (k=37) and exclusive (k=37) breastfeeding at 6 months. Pooled analyses of these trials continued to find a beneficial effect of the interventions of greater magnitude at this time point.

##### Any Breastfeeding

Thirty-seven trials (n=13,579) reported the proportion of women still breastfeeding at 6 months. The pooled relative effect indicated a beneficial association between any breastfeeding and the intervention at 6 months (RR, 1.13 [95% CI, 1.05 to 1.22]; I^2^=73.4%) (Figure 11). The prevalence of any breastfeeding was highly variable and ranged from a low of 16.7 percent^172^ to 100 percent^163^ in the intervention group, and 16.7 percent^139^ and 89.3 percent^123^ in the control group. The median absolute difference in percentage points between groups was 6 (IQR, −2.1 to 10.8).

Figure 11 Any Breastfeeding at 6 Months Pooled Analysis

Abbreviations: AUS = Australia; CAN = Canada; CG = control group; CI = confidence interval; DNK = Denmark; ESP = Spain; FRA = France; GBR = Great Britain; HKG = Hong Kong; HRV = Croatia; IG = intervention group; ISR = Israel; N = number (of participants); RR = risk ratio; SGP = Singapore; US = United States.

##### Exclusive Breastfeeding

A larger relative effect was seen for exclusive breastfeeding at 6 months, with a pooled RR of 1.46 (95% CI, 1.20 to 1.78; k=37; n=14,398; I^2^=76.8%) (Figure 12). In most studies, a greater proportion of women in the intervention groups were still exclusively breastfeeding at 6 months compared with the control groups; but eight trials found these differences to be statistically significantly different.^127,^ ^128,^ ^151,^ ^154,^ ^163,^ ^190,^ ^191,^ ^195,^ ^203^ The median absolute between-group difference in exclusive breastfeeding at 6 months was 3.2 percentage points (IQR, 0.9 to 8.7). The median in the intervention group was 14.6 percent and the median in the control group was 8.7 percent.

Figure 12 Exclusive Breastfeeding at 6 Months Pooled Analysis

Abbreviations: AUS = Australia; CAN = Canada; CG = control group; CI = confidence interval; DNK = Denmark; ESP = Spain; FRA = France; GBR = Great Britain; HKG = Hong Kong; HRV = Croatia; IG = intervention group; IRL = Ireland; ISR = Israel; ITA = Italy; N = number (of participants); NLD = Netherlands; RR = risk ratio; SGP = Singapore; TUR = Turkey; US = United States.

#### Breastfeeding at 12 Months

##### Any Breastfeeding

A meta-analysis of eight trials (n=4,607) found no statistically significant association with receiving a breastfeeding support intervention and any breastfeeding at 12 months, compared with usual care (RR, 1.04 [95% CI, 0.91 to 1.18]; I^2^=0%) (Figure 13).^123,^ ^133,^ ^156,^ ^159,^ ^171,^ ^177,^ ^199,^ ^208^ Findings of the eight studies were mixed, with four trials reporting a greater proportion of intervention women with continued breastfeeding at 12 months versus control women;^133,^ ^156,^ ^177,^ ^208^ the remaining four found trends in the opposite direction.^123,^ ^159,^ ^171,^ ^199^ Only one trial found a statistically significantly difference between groups.^177^ The absolute prevalence of breastfeeding at 12 months was highly variable, ranging from 9 percent^171^ to 85 percent.^159^ The median absolute difference in percentage points between groups was 1.3 (IQR, −1.4 to 6.1).

Figure 13 Any Breastfeeding at 12 Months Pooled Analysis

Abbreviations: AUS = Australia; CAN = Canada; CG = control group; CI = confidence interval; DNK = Denmark; GBR = Great Britain; N = number (of participants); RR = risk ratio; US = United States.

#### Prevalence as Infants Aged and Effects Over Time

Consistent with national trends, the proportion of women who reported breastfeeding declined steadily with infant age, with greater declines seen among some samples compared with other samples. Examples of the trends in absolute rates of any and exclusive breastfeeding among intervention and control groups in U.S.-based trials that reported three or more timepoints are shown in Figures 14 and 15, respectively. Although the proportion of women initiating breastfeeding was quite high (median, 85%), far fewer women in these studies continued breastfeeding compared with the U.S. national average—particularly for exclusive breastfeeding. For example, nationally, at 6 months, 59.8 percent and 27.2 percent of infants are breastfed and exclusively breastfed, respectively,^5^ whereas in the U.S. samples included in this review, the median prevalence of these same measures were 37 percent and 8.2 percent. Within the U.S.-based trials, the range of any breastfeeding at 6 months was 23.9 percent to 51.7 percent. Only two studies among predominantly White women reported that almost half of the women in both the intervention and control groups were breastfeeding at 6 months.^138,^ ^189^ The lower rates of breastfeeding seen in the included evidence may reflect attempts to recruit individuals who historically have rates of breastfeeding lower than their counterparts (e.g., Black and low-income individuals) in order to reduce known disparities.

Figure 14 Prevalence of Any Breastfeeding Over Time, U.S. Studies Only

A screenshot of a graph Description automatically generated

Figure 15 Prevalence of Exclusive Breastfeeding Over Time, U.S. Studies Only

A collage of images of a graph Description automatically generated

There were no patterns in the relative effects of the interventions over time. Some trials showed differences between groups in the prevalence of breastfeeding across time points as infants age, and some interventions effectively increased the number of women starting to breastfeed in the early weeks, but not as infants aged. Others demonstrated increasing effectiveness as infants aged (e.g., the intervention was effective at 6 months but not 3 months). This variation might reflect the variety of aims and the intensity of support over time of the respective interventions.

#### Evidence of Effect Modification

We examined whether specific population and intervention characteristics were associated with larger relative risks through tests of subgroup differences and meta-regressions. Specifically, we examined mean age of the sample, intention to breastfed at baseline, primiparity status, country, timing of the intervention, category and type of intervention (breastfeeding only vs. breastfeeding plus; professional support, peer support, general education, and other), duration of the intervention, number of sessions, and in-person versus remote intervention delivery. None of these variables were consistently associated with the effects of the interventions across outcomes nor time points, although there were a few statistically significant findings.

Larger effects were seen for any breastfeeding initiation and for any breastfeeding at less than 3 months in studies that took place in the United States versus those in other countries (any breastfeeding initiation: U.S. trials RR, 1.03 [95% CI, 1.01 to 1.06]; k=19 vs. non-U.S. trials RR, 1.00 [95% CI, 0.99, 1.01]; k=19); any breastfeeding at <3 months: U.S. trials RR, 1.10 [95% CI, 1.04 to 1.17]; k=18 vs. non-U.S. trials RR, 1.03 [95% CI, 1.01 to 1.06]; k=29). The opposite trend, however, was seen for exclusive breastfeeding at 6 months postpartum, with non-U.S. trials having larger effects (RR, 1.64 [95% CI, 1.24 to 2.17]; k=23) versus U.S. trials (RR, 1.06 [95% CI, 0.93 to 1.20]; k=14). It is unclear why this difference is apparent in the relative likelihood of starting breastfeeding among samples in the United States versus other countries. The median prevalence of breastfeeding initiation among control groups is similar in trials in the United States (85%) versus other countries (83.3%), as are the proportion of women planning to breastfeed. Similarly, it is not clear why interventions in non-U.S. settings may produce a greater effect on exclusive breastfeeding than those in the United States.

There was also an association between women’s intention to breastfeed at baseline and some outcomes. Larger effects were seen for women not intending to breastfeed versus those who were for exclusive breastfeeding initiation (RR, 1.25 [95% CI, 1.06 to 1.48]; k=18 vs. RR, 1.03 [95% CI, 0.97 to 1.09]; k=9), exclusive breastfeeding at less than 3 months (RR, 1.26 [95% CI, 1.18 to 1.36]; k=26 vs. RR 1.11 [95% CI, 1.02 to 1.20]; k=25), any breastfeeding at 6 months (RR, 1.25 [95% CI, 1.11 to 1.41]; k=16 vs. RR, 1.03 [95% CI, 0.96 to 1.10]; k=21), and exclusive breastfeeding at 6 months (RR, 1.67 [95% CI, 1.18 to 2.36]; k=119 vs. RR, 1.14 [95% CI, 0.98 to 1.33]; k=18). These findings might signal a greater likelihood for extra breastfeeding support in addition to usual care to be more effective among women who are not already intending to breastfeed.

Finally, there was some evidence of an interaction by the timing of the intervention. In studies where interventions spanned more than one period (e.g., prenatal and peripartum, peripartum and postpartum) versus those that only took place during one period (e.g., just prenatal), larger effects were seen for any breastfeeding at less than 3 months (RR, 1.10 [95% CI, 1.05 to 1.15]; k=21 vs. RR, 1.03 [95% CI, 1.01 to 1.05]; k=26), at 3 months to less than 6 months (RR, 1.13 [95% CI, 1.05 to 1.20]; k=19 vs. RR, 1.04 [95% CI, 0.99 to 1.08]; k=21), and at 6 months (RR, 1.21 [95% CI, 1.06 to 1.38]; k=18 vs. RR, 1.05 [95% CI, 0.99 to 1.13]; k=19). Similar effects were not seen for any breastfeeding at other time points, nor for exclusive breastfeeding at any time point.

These results suggest that there may be some differences in effectiveness of interventions by these characteristics; however, there may be many other differences within these studies that are driving these effects and therefore should be interpreted with this in mind. Furthermore, many of the same studies are represented in multiple time points by outcomes so patterns seen across time likely reflect the same bodies of evidence and not consistent findings across different bodies of evidence.

#### Duration of Any and Exclusive Breastfeeding

Twenty-seven trials (n=13,742) reported the effect of interventions on continuous measures of the duration of any and/or exclusive breastfeeding or time-to-event data (Appendix E Table 3).^130,^ ^134,^ ^137,^ ^138,^ ^143,^ ^144,^ ^149–152,^ ^154,^ ^155,^ ^159,^ ^161,^ ^166,^ ^167,^ ^169,^ ^185,^ ^187,^ ^189,^ ^190,^ ^192,^ ^198,^ ^200,^ ^204,^ ^207,^ ^208,^ ^210^ In these studies, breastfeeding duration was equal to the infant age (in days, weeks, or months) when the infant was no longer breastfed or exclusively breastfed. In most cases, the time-to-event or survival data reflect the risk of discontinuing breastfeeding, where a value below 1.0 reflects that women in the intervention group had a lower risk of stopping breastfeeding than women in the control group. Length of followup ranged from 8 weeks to 1 year.

In most cases, studies reported that women in the intervention group stopped any breastfeeding or exclusively breastfeeding later than women in the control groups. For any breastfeeding duration, the difference between groups in the absolute time until cessation of breastfeeding ranged from less than a day (0.5 days) to 82 days or 1 to 10 weeks. Fewer studies reported the duration of exclusive breastfeeding; in those that did, differences in groups in the absolute days of exclusive breastfeeding were 25 to 79 days or 1 to 11 weeks. These ranges in absolute values likely reflect the differences in the time point in which the followup measurement was reported or when duration was censored in the analysis.

Most studies that statistically tested the differences between groups in the time to weaning or stopping breastfeeding did not find a statistically significantly lower risk of weaning among women in the breastfeeding support interventions versus control groups at up to 6 months followup, with a few exceptions.^150,^ ^151,^ ^154,^ ^161,^ ^169,^ ^200,^ ^208^ For example, in a more recent trial of a peer telephone support intervention in Australia, women in the peer support group had a 23 percent lower risk of ceasing breastfeeding than those in the usual care group (adjusted hazard ratio [aHR], 0.77 [95% CI, 0.61 to 0.97], censored at 6 months).^150^ Similarly, a recent trial in Spain found the risk of stopping exclusive and any breastfeeding to be 63 percent (aHR, 0.37 [95% CI, 0.22 to 0.60]; p<0.001) and 61 percent (aHR, 0.39 [95% CI, 0.20 to 0.78]; p=0.008) lower among women randomized to a brief motivational intervention versus those randomized to standard education.^151^

#### Intensity of Breastfeeding

Six trials (n=1,977) reported the effects of an intervention on a measure of breastfeeding intensity (Appendix E Table 2 and Table 3).^125,^ ^130–133,^ ^156^ Intensity was variably defined as continuous scores, the proportion of feedings that were breast milk over the course of a day, or categorized according to the percent of feedings that were breast milk over the course of a day. In general, greater intensity of breastfeeding was seen among women in the intervention groups versus control groups at all time points reported.

One U.S.-based trial testing a peer counseling breastfeeding support intervention among low-income Latina women used the Index for Breastfeeding to measure the degree of breastfeeding exclusivity among participants at 2 weeks and 1, 2, and 3 months postpartum. Continuous scores on the Index for Breastfeeding were consistently higher among intervention versus control group women at all time points, indicating a higher intensity of breastfeeding (greater degree of exclusivity) among intervention compared with control group women. For instance, at 3 months, mean scores were 4.2 and 2.6 among intervention women versus control women. On this scale, a score of 4 indicates that more than 80 percent of feeds are breast milk (“high”), a score of 3 indicates that 20 percent to 80 percent of feeds are breast milk (“medium”), and a score of 2 indicates that less than 20 percent of feeds are breast milk (“low”).^130^ In another U.S.-based trial, using a similar scale, the proportion of daily feedings that were breastmilk did not significantly differ by group.^125^

Another trial focused on improving infant feeding practices to prevent childhood obesity among low-income Latino families in the United States and reported the percentage of all feedings in the past 24 hours that were breast milk based on 24-hour diet recall. At 3 months, mothers in the intervention group reported an average of 67.7 percent of all feeds were breast milk, whereas mothers in the control group reported an average of 59.7 percent of all feeds were breast milk, with a mean difference of 8 percent (95% CI, 15.3 to 0.75; p=0.03).^156^ In three separate trials by Bonuck, more women in the interventions groups were categorized as having “high” or “medium” breastfeeding intensity than women in the control group at up to 6 months to 1 year of followup.^131–133^ For example, in the PAIRINGS trial, the intervention group was more likely to report high (vs. low) breastfeeding intensity at 4 weeks (aOR, 3.65 [95% CI, 1.90 to 7.00]) and at 12 weeks (aOR, 2.79 [95% CI, 1.42 to 5.48]) and to report greater medium (vs. low) breastfeeding intensity at 6 months (aOR, 2.21 [95% CI, 1.13 to 4.32]).^132^

#### Within-Study Tests of Differences

Few studies tested if treatment effects varied by characteristics of the population. Bonuck et al. examined differences in effectiveness according to whether women were U.S.-born versus foreign-born and by race and ethnicity.^213^ There was a significant interaction according to country of origin: U.S.-born control participants had significantly lower breastfeeding intensity at both 13 weeks and 52 weeks than U.S.-born intervention participants and all foreign-born participants. In this study, race did not modify the effect of the treatment significantly.^213^ In contrast, Bender et al. found that Black race was a significant effect modifier of its text messaging intervention: among non-Black participants, there was no difference in exclusive breastfeeding rates at 6 weeks postpartum in the intervention group compared with the usual care group. However, when limiting the analysis to participants who identify as Black, a statistically higher proportion of participants in the intervention group were exclusively breastfeeding at 6 weeks postpartum compared with those in the usual care group (39.5% vs. 20.0%; OR, 2.6 [95% CI, 1.04 to 6.59]).^129^ In the study by Wallace and colleagues, there was no difference in the effects of the intervention on the prevalence of breastfeeding according to maternal age (<20, 20–29, 30–39, and >40 years), type of delivery (vaginal or caesarean), or prior breastfeeding experience (yes or no).^206^

### KQ 3 What Are the Harms of Interventions to Support Breastfeeding?

We examined all 90 included studies for any reported harms or breastfeeding “problems,” as defined by the study authors. Seven of the 90 included studies commented on the occurrence of adverse events or lack of adverse events (n=1,404);^141,^ ^142,^ ^156,^ ^175,^ ^177,^ ^182,^ ^194^ however, five of the seven studies simply reported that no adverse events were reported or that no adverse events related to the intervention were evident, but no additional details were provided. In one remaining study comparing a peer support intervention with usual care, a few mothers in the intervention group expressed feelings of anxiety, decreased confidence, or concerns about confidentiality.^142^ For example, one mother requested to discontinue her participation in the intervention, stating that the peer volunteer frightened her about the potential hazards of not breastfeeding and diminished her feelings of confidence, even though breastfeeding was going well for her. The study did not report any such adverse events among mothers in the control group. Another mother felt her right to confidentiality was violated after her peer volunteer contacted the public health department to request professional assistance without her knowledge. Another study trained data collectors to detect signs of mental health and child abuse; very few occurrences of high depressive scores and no incidences of suicidal ideation or reported suspicions of child abuse were noted in this study.^177^ As reviewed as part of KQ 1, there was no consistent evidence of greater symptoms of maternal anxiety or depression among intervention participants compared with usual care participants in six trials that reported these outcomes.

Twenty-two studies (n=13,815) reported on the incidence of breastfeeding “problems,” which were variably defined and included general breastfeeding “difficulties,” sore nipples or breasts, and cases of mastitis.^123,^ ^124,^ ^128,^ ^135,^ ^136,^ ^150,^ ^153,^ ^155,^ ^158,^ ^160,^ ^162,^ ^167–169,^ ^176,^ ^179,^ ^182,^ ^186,^ ^191,^ ^200,^ ^201,^ ^206^ In general, women in the intervention groups reported experiencing fewer breastfeeding problems than women in the control groups at all measured time points. The absolute numbers of women experiencing sore nipples and cases of mastitis were similar across studies and ranged from approximately 6 to 30 percent of women experiencing painful breasts or sore nipples in the first days to months postpartum and 3 to 8 percent of women experiencing cases of mastitis. In one study, the intervention was designed specifically to reduce breast problems (e.g., sore nipples) by teaching “biological nurturing” to women, encouraging them to breastfeed in a relaxed, laid-back position.^182^ The primary study outcome was the incidence of breast problems during the hospital stay, defined as the presence of one or more of the following outcomes, collected separately: sore nipples, cracked nipples, engorgement, and mastitis. At hospital discharge following delivery, there was a statistically significant reduced risk of breast problems (RR, 0.56 [95% CI, 0.40 to 0.79]), including cracked (RR, 0.42 [95% CI, 0.24 to 0.74]) and sore nipples (RR, 0.59 [95% CI, 0.40 to 0.88]) among women in the intervention versus usual care group despite no differences in the prevalence of exclusive breastfeeding between the groups.^182^