# Chapter 2 Methods

## Scope and Purpose

This systematic review is an update of a 2016 review.^2,^ ^3^ The scope of this updated review was changed to exclude studies of interventions that focused on health system-level policies or maternity care practices that may not be applicable to or within the purview of primary care clinicians to implement or recommend. Contextual questions (CQs) were added to address other important issues related to breastfeeding support interventions, including disparities in rates of breastfeeding and access to support interventions, and the benefits and harms of health system-level interventions. Otherwise, the scope of this review is unchanged.

## Key Questions and Analytic Framework

With input from the USPSTF, we developed an analytic framework (Figure 2) and three key questions (KQs) to guide the literature search, data abstraction, and data synthesis.

Figure 2 Analytic Framework

* For all Key Questions and Contextual Questions, “breastfeeding” refers to feeding at the breast or feeding expressed breast milk. “Breast milk” refers to human milk. When adequately delineated in source studies, precise language (feeding at the breast or feeding expressed breast milk) will be used when describing the evidence.

### KQs

1. Do interventions to support breastfeeding improve child and maternal health outcomes?
2. Do interventions to support breastfeeding improve the initiation, duration, intensity, and exclusivity of breastfeeding?
3. What are the harms of interventions to support breastfeeding?

## Data Sources and Searches

In addition to re-evaluating the studies included in the 2016 review, we also searched the following databases for relevant English-language literature published through June 3, 2024: MEDLINE, PsycINFO, CENTRAL, and CINAHL. A research librarian developed and executed the search, which was peer reviewed by a second research librarian (Appendix A). We also examined the reference lists of all included studies and previously published reviews to identify other studies for inclusion. We searched https://ClinicalTrials.gov/ for ongoing trials and have conducted ongoing surveillance for relevant literature for all bodies of evidence through January 22, 2025. We imported the literature from these sources directly into EndNote^®^ X9 (Thomson Reuters, New York, NY).

## Study Selection

We developed specific criteria to guide our study selection (Appendix A Table 1).

For all KQs, we included RCTs, including cluster RCTs. The population of interest included mothers of full- or near-term infants as well as members of the mother-infant support system (e.g., partners, grandparents, or friends). We included studies of pregnant adolescents and adults who were or were not intending to or considering breastfeeding as well as studies of those who had already given birth and were currently breastfeeding (with intervention aims to continue breastfeeding). Studies of individuals or infants requiring additional medical care were excluded (e.g., preterm infants, infants with low birth weight, infants with prenatal exposure to substances or HIV, or infants needing placement in a neonatal intensive care unit).

Included studies targeted the effects of prenatal, peripartum (at or around the time of delivery), and/or postpartum breastfeeding support interventions that were initiated in, feasible for, or referable from primary care settings. We included studies of interventions offering support that was supplementary to the standard care offered in that setting and included interventions provided by professionals, lay persons, or through digital modes of delivery. Interventions could be delivered as standalone breastfeeding support interventions (i.e., where the focus was on breastfeeding only), or be delivered as part of a wider maternal or infant health intervention if the intervention included a component focused on supporting breastfeeding. Examples of interventions with a broader focus included obesity prevention programs and interventions focused on maternal weight gain prevention.

Interventions could include elements such as reassurance, praise, information, and the opportunity to discuss and respond to the mother’s questions and could also include staff training to improve the supportive care given to individuals. Interventions could be offered to groups of individuals or families or one-on-one, including participation from support persons such as partners. Studies of interventions in prenatal, hospital, and community settings were included.

We excluded studies of health system-level interventions, including hospital or maternity care policies and implementation of the BFHI or all or some of the Ten Steps to Successful Breastfeeding. These interventions include BFHI designation, written breastfeeding policies for the facility, policies for implementing breastfeeding support groups (not breastfeeding support groups themselves), and policies to encourage rooming-in, restricted or delayed pacifier use, and maintenance of skin-to-skin contact between the mother and baby after birth. Although these types of interventions were included in the previous USPSTF review, in this update we focus on interventions that are amenable to primary care clinicians being able to provide, offer, or refer patients to. We acknowledge the importance of these interventions, however, and include a discussion of their use, effectiveness, and potential unintended harms in the Discussion section of this report (CQ 4).

Infant health outcomes included, but were not limited to, gastrointestinal illness, otitis media, respiratory illness, asthma, atopic dermatitis, and infant healthcare utilization. Maternal health outcomes included mental health symptoms, postpartum weight loss, and the incidence of breast or ovarian cancer. Breastfeeding outcomes included self-reported or observed initiation of breastfeeding, the prevalence and duration of any (i.e., non-exclusive) breastfeeding, and the prevalence and duration of exclusive breastfeeding. Detailed definitions of breastfeeding outcomes used in this report are provided in a section below. For harms, we specifically looked for harms that could be related to a breastfeeding intervention, including harms related to breastfeeding itself (e.g., cases of mastitis, nipple pain). We required that studies take place in developed countries, as defined as “very high” on the 2019 United Nations’ Human Development Index.^110^ We limited included studies to those that were deemed “good” or “fair” quality by the USPSTF quality rating standards (described below); studies of “poor” quality were excluded.

Two independent reviewers independently screened all records in the updated searches based on their titles and abstracts, using the inclusion and exclusion criteria as a guide. Subsequently, at least two reviewers assessed the full text of potentially relevant studies, including all the previously included studies, using a standard form that outlined the eligibility criteria. Disagreements were resolved through discussion and consensus. We kept detailed records of all included and excluded studies, including the reason for their exclusion.

## Quality Assessment

We quality rated all studies for potential risks of bias that may impact the reported effects and assigned each study a quality rating of “good,” “fair,” or “poor.” We applied signaling questions from the Cochrane Risk of Bias (RoB 2) tool^111^ along with the USPSTF design-specific criteria (Appendix A Table 2).^112^ Given this was an update of our own review, we did not re-quality rate the previously included studies. For new evidence, two independent reviewers rated each study. Discordant quality ratings were reviewed and discussed; a third reviewer adjudicated as needed.

Good-quality studies were those that met nearly all specified quality criteria, including whether comparable groups were assembled initially and maintained throughout the study, reliable and valid measurement instruments were used and applied equally to the groups, procedures for maintaining fidelity to the intervention were in place, followup was adequate (i.e., ≥80% retention overall) and not differential between groups, data were complete, and there was no evidence of selective reporting. Fair-quality studies did not meet these criteria but did not have serious threats to their internal validity related to the design, execution, or reporting of the study.

Studies rated as poor quality had several important risks of potential bias or one critical flaw and were excluded from this review. Potential risk of bias resulting in poor-quality ratings included very high risk of bias due to confounding and imbalances in baseline characteristics between groups, high or differential rates of attrition between groups, or no information on the number of participants with complete data or reasons for missing data, and evidence of possible selective reporting.

## Data Abstraction

One reviewer extracted key elements for each included study into standardized abstraction forms in DistillerSR. A second reviewer checked the data for accuracy. Data abstraction included general characteristics of the study (e.g., author, study design, setting), characteristics of the sample (e.g., age, intention to breastfeed), a description of the intervention (e.g., intervention type, provider, frequency, duration), definitions of outcomes (initiation and exclusivity, described in more detail below), timing of outcome assessment, analytic methods, and results. When multiple intervention arms were available, we abstracted the most intense and comprehensive intervention group as the primary arm (denoted as IG1) to be included for the analysis.

## Breastfeeding Definitions Used in the Report

We noted the specific definition of breastfeeding initiation, any breastfeeding, and exclusive breastfeeding as described by each individual study. We considered breastfeeding initiation to include any breastfeeding reported around the time of delivery up to 1 week postpartum. There are three main definitions of exclusive breastfeeding used in the literature: “exclusive breastfeeding,” according to Labbok and Krasovec (breast milk only, without any other food, fluids, water, juice, or other liquids, including vitamins or medicines);^23^ “exclusive breastfeeding,” according to the WHO (breast milk only, without any food, water, juice, or other liquids but including vitamins, minerals, and medicines);^20^ and “full breastfeeding,” as defined by Labbok and Krasovec, which includes both predominant breastfeeding (infant may consume water, water-based drinks, fruit juice, or ritualistic fluids but no infant formula) and exclusive breastfeeding (Figure 3).^23^ Within each study, we preferred measures of exclusive breastfeeding over predominant or full breastfeeding when more than one measure was reported. In many cases, the studies did not describe what they considered as exclusive breastfeeding, and we assumed they generally meant that the infant did not receive any supplementary feeding with infant formula or with complementary solid foods if before 6 months of life. We considered the prevalence of any breastfeeding to include the infant receiving any breast milk, with or without supplemental feeding with infant formula or complementary feeding with solid foods.

Figure 3 Definitions of Breastfeeding as Defined by WHO^20^ and Labbok and Krasovec^23^

Abbreviation: WHO = World Health Organization.

A picture containing text, screenshot, number, font Description automatically generated

## Data Synthesis and Analysis

We synthesized data separately for each KQ. The data on health outcomes (KQ1) and harms (KQ3) did not allow for quantitative analyses, so we summarized those data narratively. For KQ2 (breastfeeding outcomes) we conducted random effects meta-analyses using the restricted maximum likelihood estimate with the Knapp-Hartung adjustment^113^ to calculate a pooled risk ratio (RR) and 95% confidence interval (CI) for each of breastfeeding initiation, any breastfeeding, or exclusive breastfeeding. When available, we extracted author-reported RRs, and we favored author-reported adjusted RRs over unadjusted. If study-reported RRs were not available, we calculated RRs based on the number of people meeting the event criterion in each treatment group and the total number of participants randomized for each group. In this case, the RR reflects the risk of breastfeeding where values above 1.0 reflect greater breastfeeding among individuals in the intervention group versus control group. Additionally, we calculated the absolute risk difference (RD) in prevalence at each time point for each study and reported the median and interquartile range (IQR) in absolute differences.

We analyzed any breastfeeding separately from exclusive breastfeeding. We grouped the breastfeeding results into five distinct cross-sectional time points consistent with the previous review^2^ and corresponding to the U.S. Healthy People 2030 objectives:^114^ breastfeeding initiation (at birth up through 1 week postpartum) and breastfeeding at less than 3 months (2 through 11 weeks), 3 months to less than 6 months (12 through 23 weeks), 6 months (24 through 26 weeks), and 12 months (52 weeks). Each study could be included within more than one meta-analysis if it reported corresponding data. Within each study, however, we chose data from the longest time point within a given time category if more than one time point was reported (e.g., if a study reported both 12- and 20-week outcomes, we pooled the 20-week results). For breastfeeding initiation, we choose the timepoint closest to the time of hospital discharge (2–3 days postpartum). With this approach, an individual trial never contributed to more than one data point for a given pooled estimate. In addition, to avoid “double counting” in studies involving one control group and multiple intervention groups, we plotted the most intensive intervention arm (based on the number and duration of the sessions) or the arm that was the most similar with other interventions included in the analysis (noted as IG1 in tables).

In cases where a cluster RCT was used but the authors did not account for the nested nature of the data, we adjusted for the clustering effect by applying a design effect, which was based on an estimated average cluster size (i.e., the total number of randomized participants divided by the total number of clusters) and multiplied by an estimated intraclass correlation. We assumed the intraclass correlation to be 0.05.^115,^ ^116^

We examined statistical heterogeneity among the pooled studies using standard chi-squared tests and estimated the proportion of total variability in point estimates using the I^2^ statistic.^117^ We applied the Cochrane Collaboration’s rules of thumb for interpreting heterogeneity: less than 40 percent likely represents unimportant heterogeneity, 30 to 65 percent moderate heterogeneity, 50 to 90 percent substantial heterogeneity, and greater than 75 percent considerable heterogeneity.^118^

For outcomes where there were at least 10 studies, we generated funnel plots to evaluate small-study effects (a possible indication of publication bias) and performed the Peters’ test^119^ to assess statistical significance of imbalance in study size and effect sizes that suggest a pattern of larger effects in smaller studies.

We calculated the number needed to treat (NNT) for selected results by first estimating the absolute risk reduction based on the pooled RR and three levels of “baseline” rates of breastfeeding (i.e., absolute risk reduction = [RR−1]*baseline risk). Because there was a wide range of control group rates for some of the time points, we chose baseline levels empirically, using the included studies and roughly corresponding to the 25th, 50th, and 75th percentiles of control group rates at each time point for any and exclusive breastfeeding. NNT was calculated as the inverse of the absolute risk reduction.^118^

We investigated whether the heterogeneity among the results was associated with any prespecified population or intervention characteristics of the studies, first qualitatively, using visual displays and tables grouped or sorted by these potentially important characteristics. Specifically, we examined country (United States vs. others), intention to breastfeed (all intending to breastfeed vs. not), stage of pregnancy at baseline (pregnant vs. after delivery), intervention category (breastfeeding only vs. breastfeeding plus), intervention type (peer support, professional support, education, vs. other), in-person versus remote delivery, intervention timing (prenatal, peripartum, postpartum, or a combination), intervention duration, and number of intervention sessions. Based on this initial assessment, we used meta-regression and stratified analyses to examine whether the effects were different in specific subgroups. Given that there were no patterns in the effects by these various characteristics across outcomes, we present overall results for all interventions grouped together at each time point.

We were unable to pool data on continuous measures of absolute breastfeeding duration given the variability in the reported measures (means or medians), followup durations, and direction of the time-to-event data (risk of cessation of breastfeeding vs. risk of still breastfeeding); therefore, we synthesized these data in a table and narratively.

We used Stata version 16.1 (StataCorp LP, College Station, TX) for all analyses. All significance testing was two-sided, and results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center (EPC) approach,^120^ which is based on a system developed by the Grading of Recommendations Assessment, Development, and Evaluation Working Group.^121^ Our method explicitly addresses four of the five EPC-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias, and study limitations. We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., whether the evidence links the interventions directly to a health outcome).

Consistency was rated as consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as precise, imprecise, or not applicable (e.g., no evidence). The body of evidence limitations field highlights important restrictions in answering the overall KQ (e.g., suspected reporting bias, lack of replication of interventions, nonreporting of outcomes).

We graded the overall strength of evidence as high, moderate, low, or insufficient.^120^ These grades reflect our level of confidence in the estimate of effect (direction and magnitude) for benefit or harm—equating to our judgement as to how much the evidence reflects a true effect, our assessment of the level of deficiencies in the body of evidence, and our belief in the stability of the findings. The strength of evidence grade does not reflect the actual magnitude of the effect (e.g., a “small” relative risk).

A rating of “high” indicates high confidence that the evidence reflects the true effect, and that further research is very unlikely to change our confidence in the estimate of effect. “Moderate” suggests moderate confidence that the evidence reflects the true effect, and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect, and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. We developed our overall strength of evidence grade based on consensus discussion involving at least two reviewers.

## Contextual Questions

In addition to the systematically reviewed questions (KQs 1–3), we also addressed CQs to aid with the broader interpretation of the evidence. Contextual questions are important considerations that may not be readily answerable from the KQ evidence or RCT literature. Three CQs were prespecified in our Research Plan:

1. What are the associations between breastfeeding or consuming breast milk and short- and long-term child and maternal health outcomes?
2. What factors contribute to disparities in rates of breastfeeding and access to breastfeeding support interventions?
3. What programs help facilitate access to or utilization of breastfeeding support interventions? What harms are associated with these interventions?
4. Do healthcare system-level interventions and hospital policies, such as full or partial implementation of the BFHI, improve rates of breastfeeding and health outcomes? What harms are associated with these interventions?

CQs were not systematically reviewed. Evidence for CQs was identified based on literature retrieved for the systematic search for KQs as well as targeted searches and scanning bibliographies of relevant articles. A best evidence approach was used to identify the most recent, applicable, and robust evidence. CQs are addressed in the Introduction and Discussion sections of this report.

## Expert Review and Public Comment

A draft research plan including the Analytic Framework, KQs, and inclusion and exclusion criteria was posted on the USPSTF website for public comment from March 10 to April 16, 2022. Most comments, while informative, pertained to details and considerations for background information and data abstraction and analysis. There were no changes made to the research plan that changed the scope of the review or our approach to synthesizing the evidence. A final research plan was posted on the USPSTF website on July 14, 2022.

A draft version of this report was reviewed by four invited experts and three individuals at USPSTF Federal Partner agencies. Experts were selected based on their expertise with fundamental methodologic and content aspects of the review and were selected to obtain diverse informed perspectives. All expert comments were considered, and selected comments from experts were used to clarify and extend the synthesis of evidence to ensure accuracy and address scientifically relevant concerns. All comments were shared with members of the USPSTF and AHRQ.

In addition, the draft evidence report was posted on the USPSTF website for public comment from October 22, 2024, through November 18, 2024. All comments were reviewed and considered. We reviewed several citations that were recommended within these comments. Most studies did not meet inclusion criteria due to study designs or aim; however, a few citations were added to provide additional contextual information.

## USPSTF and AHRQ Involvement

We worked with USPSTF members at key points throughout this review, particularly when determining the scope and methods and developing the Analytic Framework and KQs. The USPSTF members approved the final Analytic Framework, KQs, CQs, and inclusion and exclusion criteria after revisions reflecting the public comment period. AHRQ staff provided oversight for the project, coordinated systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.