# Chapter 1 Introduction

## Current USPSTF Recommendation and Purpose of Review

In 2016, the U.S. Preventive Services Task Force (USPSTF) concluded that there was adequate evidence that interventions to support breastfeeding, including professional support, peer support, and formal education, increase the duration and rates of breastfeeding and that the harms of these interventions were no greater than small.^1^ Therefore, the USPSTF concluded with moderate certainty that interventions to support breastfeeding have a moderate net benefit and recommended providing interventions during pregnancy and after birth to support breastfeeding (B recommendation).

The Agency for Healthcare Research and Quality (AHRQ) has requested an updated evidence report on interventions to support breastfeeding to support an updated recommendation by the USPSTF. This report updates the 2016 review.^2,^ ^3^

## Condition Definition

Historically, the term breastfeeding referred to the simultaneous dyadic behavior of a mother feeding her infant at her breast. However, there are an increasing number of behaviors often encompassed by the word “breastfeeding.”^4^ Most recommendations use the term “breastfeeding” when referring to the behavior, but it is typically measured by assessing the child’s intake of breast or human milk, regardless of who produced it or whether it was obtained directly at the breast or from a spoon, cup, or bottle. Consumption of breast milk can be accomplished by feeding at the breast (also referred to as at-the-breast feeding or direct breastfeeding) or expressed breast milk feeding from the mother or from donor sources. The behavior is measured in terms of initiation of the behavior, duration of breastfeeding or consumption of breast milk, exclusivity of only consuming breast milk (without other liquid or food supplementation), or intensity (the proportion of all feedings that included breastmilk) and can be reported since birth or within the past 24 hours.

We use the term breastfeeding when referring to both feeding at the breast and feeding expressed breast milk (including shared, donated, and purchased breast milk), unless specifically noted.

## Prevalence of Breastfeeding

In observing the prevalence of breastfeeding in the United States, a pattern emerges indicating a sharp decline in breastfeeding rates as infants age, with breastfeeding most prevalent from initiation to shortly after birth and steadily dropping off throughout the first year of the infant’s life (Figure 1).^5^ In 2021, among the infants born in the United States, the estimated breastfeeding rates were 84.1 percent for initiation, 59.8 percent for infants breastfed at 6 months, and 39.5 percent for infants breastfed at 1 year (Table 1). In the same year, the rates of exclusive breastfeeding through 3 and 6 months were 46.5 and 27.2 percent, respectively.

Figure 1 Rates of Any and Exclusive Breastfeeding by Age Among Children Born in the United States in 2021^5^

Note: Figure sourced from the Centers for Disease Control and Prevention and National Immunization Survey.^5^

A graph of a baby age Description automatically generated with medium confidence

Table 1 Current Rate of Breastfeeding by Sociodemographic Characteristics, 2021^5^

Breastfeeding Outcome | Timing | US National | Maternal Age <20 years | Maternal Age 20–29 years | Maternal Age ≥30 years | White^*^ | Black^*^ | Hispanic | Asian^*^ | Hawaiian/Pacific Islander^*^ | American Indian/Alaska Native^*^ | Multiracial
Any BF^†^ | Ever^§^ | 84.1 | NA | 80.0 | 86.1 | 86.2 | 75.4 | 83.4 | 92.7 | NA | NA | 85.2
Any BF^†^ | At 6 months | 59.8 | NA | 49.8 | 64.8 | 63.4 | 51.7 | 56.1 | 73.9 | NA | NA | 58.4
Any BF^†^ | At 1 year | 39.5 | NA | 32.7 | 42.9 | 42.5 | 31.0 | 37.0 | 50.8 | NA | NA | 38.9
Exclusive BF^║^ | Through 3 months | 46.5 | NA | 43.9 | 47.8 | 50.3 | 39.0 | 45.6 | 46.0 | NA | NA | 43.2
Exclusive BF^║^ | Through 6 months | 27.2 | NA | 25.2 | 28.7 | 29.2 | 24.4 | 25.9 | 30.2 | NA | NA | 23.2

Abbreviations: BF = breastfeeding; NA = not applicable, estimate not available because the 95% CI was mostly greater than 10 in these subgroups.

* Non-Hispanic.

† Any breastfeeding or being fed breast milk.

§ Ever breastfed or fed breast milk.

║ Exclusive breastfeeding is defined as ONLY breast milk—NO solids, water, or other liquids.

Several sociodemographic characteristics are associated with the likelihood of breastfeeding initiation and continuation. Characteristics consistently shown to be associated with higher rates of breastfeeding include older age, being married, higher education, higher socioeconomic status, and access to private insurance.^6–8^ Additionally, data continuously show lower rates of breastfeeding among infants born to Black women and higher rates among Asian, White, and Hispanic women (Table 1).^5^ Specifically, among infants born in 2021, the rate of any breastfeeding was lowest in infants born to Black women at 75.4 percent, compared with 83.4 percent for infants born to Hispanic women, 86.2 percent for infants born to White women, and 92.7 for infants born to Asian women.^5^ There is evidence that intention to breastfeed does not necessarily correlate with high rates of breastfeeding and that there are pronounced gaps between intention and goal-achievement among minority women. A longitudinal analysis of a cohort of over 2,000 women enrolled in the Special Supplemental Nutrition Program for Women, Infants, and Children (WIC) found that while women of all races have similar rates of prenatal intention to breastfeed their infants, Black and Hispanic women have lower odds of meeting their breastfeeding goals at 1 and 3 months compared with White women.^9^

With regard to education, women who have a high school education are almost half as likely (27.6%) to breastfeed infants at 12 months than women who graduate college (50.0%).^5^ Further, persons who are part of the WIC program are less likely to breastfeed infants at 6 months than persons who are ineligible for the program (76.9% and 91.6%, respectively).^10,^ ^11^ Married women are more likely to breastfeed infants at 6 months than those who are unmarried (69.9% vs. 44.0%, respectively), as are women who live in metropolitan areas compared with women who live in rural settings (61.0% vs. 50.8%, respectively).^5^ Finally, women ages 20 to 29 years are less likely to breastfeed infants at 6 months than those age 30 years or older (49.8% vs. 64.8%, respectively).^5^

There are also large variations in the rates of breastfeeding initiation and continuation around the world, although the specific indicators and dates during which the data were collected differ. Worldwide, it is estimated that 47.7 percent of infants younger than age 6 months were exclusively breastfed in 2021, which is an increase from 37 percent reported in 2012.^12,^ ^13^ There are disparities reported, however, between high-income countries and low-middle income countries, with 96 percent of infants ever receiving breast milk in low-middle income countries compared with 79 percent of infants in high-income countries.^14^ In 2016–2018, among high-income countries, the countries with the lowest rates of breastfeeding initiation were Ireland (55.0%), France (63.0%), and the United States (74.4%).^14^ The variation in breastfeeding rates is not seen just between high-income and low-middle income countries, but also between different socioeconomic groups within countries. Research has shown that in high-income countries, individuals from lower-income households are less likely to breastfeed, whereas in low-middle income countries, individuals from wealthier households are less likely to breastfeed.^8,^ ^14^

## Recommendations for Breastfeeding

Multiple national and international organizations, including the American Academy of Pediatrics (AAP, 2012),^15^ the American Academy of Family Physicians (AAFP, 2015),^16,^ ^17^ the American College of Obstetricians and Gynecologists (ACOG, 2018),^18^ the 2020–2025 Dietary Guidelines for Americans,^19^ and the World Health Organization and the United Nations Children’s Fund (WHO/UNICEF, 2003),^20,^ ^21^ recommend that infants be exclusively fed breast milk for the first 6 months of life, followed by continued breastfeeding for at least 1 year, as mutually desired by mother and infant, while complementary foods are introduced. Recently, the AAP updated its guidance to emphasize supporting mothers who choose to breastfeed for 2 years or longer.^22^

Various definitions for exclusive breastfeeding exist,^23,^ ^24^ but exclusive feeding typically means the infant does not receive any additional foods, supplements (except vitamin D), or fluids unless medically recommended. Breastfeeding measures are included in the Healthy People 2030 goals and include increasing the proportion of infants who are breastfed exclusively through 6 months of age (42.4%)^25^ and increasing the proportion of infants who are breastfed at 1 year (54.1%).^26^

## Association Between Breastfeeding and Breast Milk and Child and Maternal Outcomes (Contextual Question 1)

Breastfeeding and the consumption of human milk is widely accepted as the most beneficial feeding method for infants. Decades of research indicate that breastfeeding is associated with short- and long-term benefits for children and mothers. To date, the most comprehensive and widely cited systematic review on the relationship between breastfeeding and both infant and maternal health outcomes is a 2007 report prepared by Ip and colleagues.^27^ This review, which synthesized both primary studies and existing systematic reviews, was evaluated by the USPSTF as part of its deliberations in making its 2009 recommendation. Several recent systematic reviews, including a 2025 update on the evidence on child health outcomes,^28^ have been published that present findings consistent with the original 2007 report and provide additional data for outcomes with previously limited or otherwise insufficient data. A summary of the synthesized evidence for infant and child and maternal outcomes is provided in Table 2 and described narratively below.

Table 2 Association Between Breastfeeding and Health Outcomes From Recent Existing Systematic Reviews

Outcome | k | Finding
Infant
Acute otitis media^304^ | 5 | Ever vs. never BF associated with reduced risk of acute otitis media (OR, 0.67 [95% CI, 0.56 to 0.80]).
Asthma^29^ | 36 | Longer vs. short duration of any breastfeeding associated with reduced risk of asthma among children age <18 years (OR, 0.84 [95% CI, 0.75 to 0.93]).
Atopic dermatitis^48^ | 27 | No association between longer vs. shorter durations of any or exclusive breastfeeding and atopic dermatitis at 1-17 years.
Celiac disease^50^ | 16 | No association between longer vs. shorter durations of breastfeeding, with inconsistency and imprecision in effects.
CVD outcomes | 46 | Limited evidence suggests that ever vs. never being fed human milk is associated with blood pressure within a normal range. The evidence is less clear for diastolic blood pressure and longer vs. shorter durations of breastfeeding. Evidence about the relationship of never vs. ever being fed human milk with blood lipids in childhood was inconclusive, and there was insufficient evidence to determine the relationship of never vs. ever being fed human milk with endpoint cardiovascular disease outcomes, blood pressure and blood lipids in adolescence or adulthood, metabolic syndrome, and arterial stiffness.
Childhood leukemia^35,^ ^305^ | 33 | Ever vs. never breastfed associated with a reduced risk of childhood leukemia (RR, 0.77 [95% CI, 0.65 to 0.91]); similarly, “more” vs. “less” breastfeeding associated with a statistically significant reduced risk of childhood cancer (RR, 0.77 [95% CI, 0.63 to 0.94]).
Cognitive development^47^ | 84 | No association between breastfeeding and cognitive ability in infants, children, or adults after controlling for variables known to be correlated with breastfeeding and intelligence quotient.
Dental caries^306^ | 31 | No association between ever vs. never breastfeeding and the development of dental caries in early childhood. Longer vs. shorter duration of breastfeeding (12 months or longer) was associated with a 54 percent greater risk of developing dental caries in childhood (RR, 1.54 [95% CI, 1.16 to 2.00]).
Diabetes mellitus: type 1^42^ | 43 | Statistically significant reduced odds of type 1 diabetes with “more” vs. “less” breastfeeding (OR, 0.74 [95% CI, 0.64 to 0.84]) and “more” vs. “less” exclusive breastfeeding (OR, 0.81 [95% CI, 0.72 to 0.92]).
Diabetes mellitus: type 2^41^ | 4 | Insufficient evidence on the relationship between breastfeeding and the risk of type 2 diabetes at any age.
Gastrointestinal infection^36^ | 8 | Consistent protective association of breastfeeding and moderate-to-severe cases of gastrointestinal infection that varied in magnitude according to breastfeeding duration and exclusiveness.
Inflammatory bowel disease^40^ | 42 | Potential protective association between more or longer duration of breastfeeding vs. less and inflammatory bowel disease at 5 years and older.
Moderate-to-severe respiratory tract infection^36,^ ^307^ | 16 | Consistent protective association of breastfeeding and moderate-to-severe respiratory tract infections, including lower and upper respiratory infections and RSV.
Rapid weight gain, growth trajectory, and obesity^32,^ ^33,^ ^308^ | 159 | Possible protective association with lower likelihood of experiencing rapid weight gain from birth to 12 months with exclusive or greater durations of breastfeeding and consistent evidence that breastfeeding is associated with a reduced risk of overweight and obesity in children 2 to 12 years old.
All-cause mortality^28^ | 3 | Three large cohort studies in the United States suggest a potential protective association between breastfeeding initiation and infant mortality.
Maternal
Breast cancer^52,^ ^53^ | 98 | Ever vs. never BF associated with lower risk of breast cancer (OR, 0.78 [95% CI, 0.74 to 0.82])
Breast cancer^52,^ ^53^ | 50 | Lifetime BF ≥12 mo vs. never associated with lower risk of breast cancer (OR, 0.74 [95% CI, 0.69 to 0.79])
Ovarian cancer^52,^ ^53^ | 41 | Ever vs. never BF associated with lower risk of ovarian cancer (OR, 0.70 [95% CI, 0.64 to 0.77])
Ovarian cancer^52,^ ^53^ | 29 | Lifetime BF ≥12 mo vs. never associated with lower risk of ovarian cancer (OR, 0.63 [95% CI, 0.56 to 0.71])
Hypertension^53^ | 5 | Consistent association between longer duration of BF (>6-12 mo) and lower rates of HTN; magnitude of association varies by BF exposure comparisons and study design
CVD^53^ | 3 | Unclear association between BF and CVD; three studies conclude an association between longer BF duration and lower CVD rates, each using a different composite outcome; magnitude of association varies by exposure comparisons, age at cohort enrollment, and study design
Diabetes mellitus: type 2^53,^ ^54^ | 6 | “Longer” vs. “shorter” duration of lifetime BF associated with reduced risk of type 2 diabetes (OR, 0.68 [95% CI, 0.57 to 0.82])
Postpartum depression^53,^ ^55^ | 62 | Magnitude of association and direction of effect unclear
Postpartum weight change^53^ | 16 | Magnitude of postpartum weight change varies by BF exposure and outcome measure

Abbreviations: BF = breastfeeding; CI = confidence interval; CVD = cardiovascular disease; HTN = hypertension; IBD = inflammatory bowel disease; k = number of studies; mo = month; OR = odds ratio; RR = risk ratio; SIDS = sudden infant death syndrome; y = years.

“More” versus “less” breastfeeding has been found to be associated with a reduced risk of a variety of health outcomes in infancy and childhood,^28^ including acute otitis media, asthma,^29,^ ^30^ rapid weight gain and obesity,^31–33^ childhood leukemia,^34,^ ^35^ moderate-to-severe respiratory infections and gastrointestinal infections in infants,^36^ allergic rhinitis,^37^ malocclusion,^38,^ ^39^ inflammatory bowel disease,^40^ type 1 diabetes,^41,^ ^42^ elevated blood pressure,^43^ and infant mortality.^44,^ ^45^ The most recent national study examining the relationship between breastfeeding and infant mortality reported a 33 percent reduced risk of early post-perinatal (7 to 182 days) and post-perinatal (7 to 364 days) deaths in children who did versus did not initiate breastfeeding.^46^ For most of these outcomes, limited but consistent evidence suggests that shorter versus longer durations of breast milk feeding is associated with higher risk of these negative health outcomes. The evidence suggests no association or is insufficient^28^ to suggest a clear link between breastfeeding and cognitive development,^47^ atopic dermatitis,^30,^ ^48^ celiac disease,^49,^ ^50^ food allergies,^30,^ ^51^ and type 2 diabetes.^41^ The evidence is extremely limited when assessing the relationship between the intensity, proportion, or amount of breast milk fed to mixed-fed infants or fed by bottle versus by breast and all of these outcomes.^28^ Furthermore, as discussed below, there are considerable limitations related to understanding and interpreting these relationships.

Regarding maternal health outcomes, a history of breastfeeding and/or breastfeeding for longer durations may be associated with a reduced risk for breast and epithelial ovarian cancers,^52,^ ^53^ hypertension,^53^ and type 2 diabetes.^53,^ ^54^ In contrast, no clear relationship between a history of breastfeeding and the risk of fractures has been found to date,^53^ and the associations between breastfeeding and the mother’s return to pre-pregnancy weight and postpartum weight loss,^53^ the prevalence of postpartum depression,^53,^ ^55^ and cardiovascular disease^53^ have been negligible or unclear.

The evidence regarding the relationship between breastfeeding and health outcomes is based primarily on observational research, since it is unethical to randomize individuals to breastfeed or not breastfeed. Compared with randomized clinical trials (RCTs), observational research has well-recognized sources of potential bias, including possible selection bias, misclassification, unmeasured or uncontrolled confounding, reverse causality, and publication bias. In addition, exposure to breastfeeding is measured and reported differently across observational studies, including the comparisons made (e.g., ever vs. never breastfeeding, or breastfeeding for 6 vs. 3 months), the definition of breastfeeding (including not distinguishing between any vs. exclusive breastfeeding), and the age at which infant and child outcomes were measured. These studies also differ in their measurement and operationalization of the infant and maternal outcomes, study setting, and the statistical adjustment for potential confounders.

## Breastfeeding Interventions

Interventions to support breastfeeding can be delivered directly to mothers and their support persons or be focused on system-level policies or maternity care practices aimed at creating an environment supportive of breastfeeding. Interventions can occur over the course of pregnancy (prenatal), the time around and shortly after delivery (peripartum), and/or after birth (postpartum). Non-healthcare breastfeeding support interventions may include community breastfeeding promotion or support; worksite policies and programs; childcare policies and practices; and legislation, including family leave policies.^56,^ ^57^

Interventions can include individual professional or peer support, structured education, or a combination of support modalities. Breastfeeding support can be comprised of psychological and social support (e.g., encouraging the mother, providing reassurance, discussing the mother’s questions and problems), as well as direct support during breastfeeding observations (e.g., helping with the positioning of the infant, observing latching), and is typically offered in addition to general education.^18,^ ^56,^ ^58,^ ^59^ This type of support usually begins shortly after birth in the hospital setting or other birthing facility and may continue after the hospital stay. Conversely, breastfeeding education typically includes a formalized program aimed at conveying nontailored breastfeeding knowledge and most often occurs in the prenatal period.^56^ Within this framework, education is usually offered in group sessions and may involve telephone support, electronic interventions, and print materials. Individual-level interventions may be conducted by medical, nursing, or allied professionals (such as lactation care providers) or lay people (such as peer supporters).^18,^ ^56,^ ^58,^ ^59^

Support for breastfeeding may work in different ways for different individuals. In some cases, it may be important to include extra breastfeeding support prenatally to discuss the benefits of breastfeeding, discuss family goals, and plan accordingly. Interventions may increase individual’s beliefs in the importance of breastfeeding, particularly in settings where breastfeeding may not be the norm. Interventions can help increase individual’s self-efficacy in their abilities to make feeding choices for their infant and give them confidence to continue breastfeeding in the face of familial and societal pressures that might otherwise undermine breastfeeding. Additionally, timely, skilled support at or around the time of birth and postpartum can help individuals to avoid or overcome breastfeeding problems that often lead to stopping breastfeeding. Support that continues until the time parents may have to return to work can help empower and provide support to overcome challenges that are often encountered with that transition.

System-level interventions include policies or maternity care practices such as the implementation of the Baby-Friendly Hospital Initiative (BFHI)^60^ or all or some of the Ten Steps to Successful Breastfeeding (Table 3).^61^ These interventions may include a written breastfeeding policy for the facility, provider or staff training in breastfeeding support, policies for implementing breastfeeding support groups, encouragement of rooming-in, restricted or delayed pacifier use, maintenance of skin-to-skin contact between the mother and baby after birth, and encouragement of early breastfeeding initiation.^18,^ ^56,^ ^58^ Recently, the BFHI and the Ten Steps to Successful Breastfeeding were updated to consider newer evidence and healthcare practices.^62^ Overall, the conclusions remained the same; however, there were updates to the wording of some of the steps and slight changes to the way the steps were organized. In addition, the updated guidance on BFHI includes recommendations to allow states to improve coverage and standards in BFHI implementation, such as scaling up BFHI coverage in both public and private facilities, integrating the BFHI into existing initiatives in health systems, and regular monitoring to ensure standards are maintained. While system-level interventions such as these may be important interventions to support breastfeeding, they are not included in our synthesis of the evidence given our focus on interventions that can be supported by primary care clinicians. Rather, we provide contextual information about these types of interventions in the Discussion chapter of this report.

Table 3 WHO/UNICEF BFHI Ten Steps to Successful Breastfeeding^61^

[underlined: Critical management procedures]; 1a. Comply fully with the International Code of Marketing of Breast-milk Substitutes and relevant World Health Assembly resolutions.; 1b. Have a written infant feeding policy that is routinely communicated to staff and parents.; 1c. Establish ongoing monitoring and data-management systems.; 2. Ensure that staff have sufficient knowledge, competence, and skills to support breastfeeding.
[underlined: Key clinical practices]; 3. Discuss the importance and management of breastfeeding with pregnant women and their families.; 4. Facilitate immediate and uninterrupted skin-to-skin contact and support mothers to initiate breastfeeding as soon as possible after birth.; 5. Support mothers to initiate and maintain breastfeeding and manage common difficulties.; 6. Do not provide breastfed newborns with any food or fluids other than breast milk, unless medically indicated.; 7. Enable mothers and their infants to remain together and to practice rooming-in 24 hours a day.; 8. Support mothers to recognize and respond to their infants’ cues for feeding.; 9. Counsel mothers on the use and risks of feeding bottles, artificial nipples (teats) and pacifiers.; 10. Coordinate discharge so that parents and their infants have timely access to ongoing support and care.

## Factors Contributing to Disparities in Rates of Breastfeeding and Access to Interventions (Contextual Question 2)

There are a multitude of factors that contribute to the disparities in the rates of breastfeeding and access to breastfeeding support interventions observed among populations in the United States. These factors are complex and include elements at a personal level, such as the culture of the individual and their personal support system, as well as broader reaching elements such as ingrained bias in healthcare interactions, availability of extended maternity leave, lack of availability of lactation rooms and time to pump in the work environment, neighborhood resources, and programmatic norms.^7,^ ^8,^ ^63–67^ Understanding these variables is important in closing the gap in breastfeeding initiation and continuation.

Studies have found that social and cultural variables can play a significant role in an individual’s decision making around breastfeeding and their ability to continue breastfeeding if they choose to initiate this feeding method. It has been shown that support from an individual’s family, their nonfamilial social support, and whether they have positive social modeling of breastfeeding around them are incredibly influential in predicting breastfeeding intention, continuation, and duration.^68–70^ For example, research has shown that matriarchal role models such as mothers and grandmothers are an integral part of the culture in the Black community and are often very involved in the raising of children and grandchildren.^68,^ ^71,^ ^72^ Therefore, the views that these women have towards breastfeeding may be important in shaping the decision among younger generations to breastfeed and for how long.

Further, in the African American community in the United States there is a complicated history around breastfeeding that goes back to the days of slavery.^66,^ ^69–71,^ ^73^ Historically, African American women were often forced to act as wet nurses for their slave owner’s children and therefore some Black women report a stigma associated with breastfeeding that continues to persist.^68,^ ^69,^ ^72,^ ^74^ Additionally, among older generations, studies among both African American and other communities have shown that formula feeding was associated with wealth because if you could afford the cost of infant formula you would do so and if you could not you would breastfeed.^72^ From this you can see the potential bias towards formula feeding among women of older generations, which in cultures where matriarchal support is common in child rearing is important to be aware of. Another historical component that may come into play in present day decision making around infant feeding is predatory marketing of infant formula to Black families. In the 1950s, the PET milk company used targeted advertisements and instilled brand loyalty, as well as feelings of status associated with using its products among those in this community.^58,^ ^75^

There are also often misconceptions around the benefits of breastfeeding versus formula feeding among support individuals, and conflicting advice given in general around feeding decisions that can negatively impact breastfeeding initiation and duration.^69,^ ^70,^ ^72^ For example, in the Black community it has been reported that mothers are commonly advised against breastfeeding infants by their relatives, peers, and neighbors because breastfeeding an infant can cause them to become overly dependent on the mother, whereas formula feeding is an inexpensive option that required less time and allowed them to maintain their social life.^69^ In the Hispanic and Latino community there is a concept of “los dos,” which means “both” and refers to the idea that providing both breast milk and infant formula gives infants twice the benefits.^76–78^ Therefore, this could play a role in the reported finding of higher rates of supplementation with infant formula in these communities than what is seen among communities made up of predominantly non-Hispanic White individuals.^76,^ ^78^

Another social factor shown to influence decisions around infant feeding is the over-sexualization of women’s bodies, notably Black women, including their breasts, in pop culture and the media, which emphasizes their use for sexual purposes and not for nutrition.^66,^ ^69,^ ^70,^ ^72,^ ^73,^ ^79^ This likely shapes the views that their partners may have towards breastfeeding and their likelihood of supporting or encouraging breastfeeding.

In addition to an individual’s support environment and cultural surroundings, a person’s physical health has been shown to be related to infant feeding. Specifically, lower rates of breastfeeding initiation and reduced duration of breastfeeding have been reported by individuals with a high pre-pregnancy body mass index (BMI).^80–83^ Further, the risk of early breastfeeding cessation has been shown to increase as BMI increases.^84^ The reasons for these trends are complex and likely confounded by social determinants of health. However, the relationship among high BMI, race and ethnicity, and breastfeeding rates is important to consider when evaluating the possible causes of breastfeeding disparities among populations of color because research has shown that among Black and Hispanic and Latino populations there are higher rates of individuals with obesity compared with predominantly White communities.^85,^ ^86^ When looking into the reasons for poor breastfeeding outcomes among individuals with obesity, biological factors have been hypothesized. Research has suggested that individuals with obesity may experience a delay in their milk coming in after delivery due to hormonal factors and that there may be a reduced prolactin response to infant feeding during the early postpartum period.^80–83^ Since perceptions of having inadequate milk supply have been tied to early cessation of breastfeeding, this is noteworthy. In addition, women with obesity may have larger breasts, which evidence shows can complicate breastfeeding positioning, as well as flat nipples, which can increase the risk of improper latching and frustration around feeding.^80–82,^ ^87^ Having to adjust feeding positioning to accommodate additional body tissue can further complicate finding an efficient and comfortable feeding routine.^80–82,^ ^87^ A recent qualitative study reported that women with obesity described breastfeeding taking a significant amount of time due to the need of additional physical aids, such as pillows, to make feeding comfortable and that this limited the places outside of the home that they felt comfortable feeding their infant.^81^ This finding touches on the social judgement that individuals with obesity report as a factor that influence their infant feeding decisions. Women with obesity have reported feeling uncomfortable breastfeeding in public due to the social stigma around their weight and that the anxiety that they feel around revealing their bodies or finding comfortable places to breastfeed their infants away from home has influenced their decision to stop breastfeeding.^80–82,^ ^87^ Further, barriers around finding proper fitting nursing attire such as comfortable nursing bras in larger sizes, as well as experiencing reduced lactation support from healthcare providers due to healthcare stigma have been reported to contribute to the poor breastfeeding outcomes observed in this population.^80,^ ^81,^ ^88^

Other important factors that research has shown to impact an individual’s ability to breastfeed or access breastfeeding support are related to institutional norms and structural determinants of health, such as inflexible work hours, lack of paid family leave, access to lactation services, and neighborhood resources.^58,^ ^70,^ ^74,^ ^77,^ ^89^ It is common for Black, Hispanic and Latino, and individuals with lower socioeconomic status to work in jobs that do not offer flexible hours that would help to support breastfeeding or pumping while at work or provide extended family leave.^66,^ ^74,^ ^89^ Extended family leave is generally lacking in the United States, but it is common to return to work at around 12 weeks after giving birth. Research has shown, however, that Black women generally return to work after just 6 to 8 weeks postpartum.^66,^ ^72^ This difference is notable when considering the potential barrier of finding time to pump while at work and the possibility that the workplace norm may be to discourage time away to do so. Further, a 2018 report found that lactation discrimination (e.g., denying pumping breaks, refusing to provide a private place to pump) in the workplace was widespread, resulting in notably harsh effects such as docking of wages or job loss for low-wage workers, who are more likely to be Black or Hispanic individuals.^90^ An analysis of the Black Women’s Health Study (N=2,172) found that just over half of the women surveyed reported experiencing racism on the job and that among those who reported experiencing racism on the job there were significantly lower odds of breastfeeding for 3 to 5 months.^89^ Limited or substandard access to employer-provided breastfeeding support, which research shows primarily affects lower-income women of color, further impacts the disparities in breastfeeding rates among these groups.

Research has also shown that where individuals live can impact their decisions around infant feeding. Lower-resourced neighborhoods often lack access to breastfeeding support resources and concerns about safety have been found to be negatively associated with breastfeeding initiation and duration.^58,^ ^91,^ ^92^ In a recent cohort study in the United Kingdom (n=17,308), researchers found that as neighborhood deprivation increased, the odds of breastfeeding initiation decreased.^92^ Further, the analysis showed that breastfeeding initiation, exclusivity, and duration were each reduced by approximately 20 percent among individuals who felt that their neighborhoods were unsafe for children to play in compared with neighborhoods where it was felt that it was safe for children to play.^92^ A recent U.S.-based cohort study (n=29,829) found similar trends, with the rates of breastfeeding initiation and exclusive breastfeeding at 6 months being significantly higher among children whose parents feel that their child is “always” or “usually safe” in their neighborhood, who live in neighborhoods with more amenities, and who receive care in a medical home.^91^ The reason for these findings are likely complex and are due to the interplay of many social determinants of health; however, they show that feeding decisions are impacted by both the larger environment as well as the individualized home environment.

Over the past decade, there has been a growing recognition that disparities in access to breastfeeding support, including maternity care practices^63,^ ^72,^ ^89,^ ^93–95^ and the credentialing of lactation care providers^96,^ ^97^ of various races, ethnicities, sexual or gender identities, and income levels are crucial aspects in addressing the disparities in rates of breastfeeding.^70,^ ^98,^ ^99^ A recent study of breastfeeding support policies found that facilities located in zip codes with higher percentages of Black residents than the national average were less likely to meet the five indicators for supportive breastfeeding practices (early initiation of breastfeeding, rooming-in, limited use of breastfeeding supplements, limited use of pacifiers, and post discharge support) than facilities located in areas with a lower percentage of Black residents.^93^ Further, for Black and Hispanic or Latina women, the WIC program is a vital source of breastfeeding support and guidance for new mothers; however, the amount and quality of breastfeeding support given by WIC counselors has been found to differ by race and ethnicity.^95,^ ^100,^ ^101^ The WIC program has tried to remedy this disparity through increased education, peer support, and trained lactation consultants; however, given the persistent disparity in breastfeeding rates among WIC participants and individuals not in the program, there remains a continued opportunity for improvement.^102^

Overall, studies have shown that Black individuals often receive fewer healthcare services and may be less likely to receive breastfeeding education or support than White individuals.^63,^ ^65,^ ^95,^ ^103–105^ The reasons for this are complex; the literature shows that historical institutional racism has resulted in Black individuals regularly being denied access to high-quality, equitable healthcare.^95^ For example, a recent study (N=2,138) found that 1 in 6 Black women who received maternity services reported experiencing inequitable treatment during the perinatal period.^106^ A qualitative study of certified lactation consultants found that the majority had witnessed breastfeeding discrimination by healthcare providers (physicians, nurses, and other lactation consultants) by the providers making the assumption that Black women would not choose to breastfeed their infants, and therefore they made fewer requests for lactation services for those patients.^105^ This resulted in reduced breastfeeding support compared with White patients. Further, Black patients initiating breastfeeding while in the hospital have reported limited assistance if issues with breastfeeding arose and even report receiving advice or care that discouraged breastfeeding.^95^ Although these disparities in care are acutely felt by Black patients, they are not exclusive to them. Black, Asian, Hispanic and Latino, and Native American/Alaska Native patients have reported inequitable perinatal care at higher rates than White patients. Specifically, 13 percent of both Black and Asian patients, 12 percent of Hispanic patients, and 11 percent of Native American/Alaska Native patients reported being ignored by their healthcare provider or having their requests for information refused, compared with 5.6 percent of White patients.^106^ Additionally, more than twice the number of individuals in these specific populations reported being shouted at by their healthcare provider than White individuals (13% vs. 6%, respectively). A qualitative study of Black women and healthcare providers who serve communities with predominately Black populations found that the women participating in the panel discussions described feeling like they did not have a voice in interactions with hospital staff during the birthing process, that their birthing plans were ignored, and that they felt alienated and bullied.^107^ This lack of support continued into their experiences around breastfeeding and highlight the need for equitable, culturally sensitive healthcare in order to help improve the existing disparities that are observed in breastfeeding rates among these communities.

## Current Clinical Practice in the United States

There is very little current data regarding clinical practice related to breastfeeding support interventions. However, a recent 2022 study examined state-level breastfeeding support and breastfeeding practices, utilizing publicly available data, and found that in 2015, nationwide availability of International Board of Lactation^®^ Consultants (IBCLCs) per 1,000 births ranged from 1.9 to 13.4 and La Leche League Leaders (volunteer breastfeeding counselors) per 1,000 births ranged from 0.2 to 3.3. This same study found that the percentage of births occurring in Baby-Friendly Hospitals ranged from 0 to 47.4 percent.^108^

A study conducted in a nationally representative sample of mothers with infants 2 to 6 months old (N=1,031) found that in 2015, many women did not receive any advice on breastfeeding from a healthcare provider or reported receiving advice that was inconsistent with AAP policy and practice recommendations during the peripartum period.^109^ The study also found that when a doctor was the source of advice, 21.8 percent of mothers did not receive any guidance on breastfeeding, and 15.4 percent of mothers were given advice that was inconsistent with recommendations. Similarly, when nurses were the source of advice, 13.3 percent of mothers did not receive any advice, while 14.4 percent of mothers received advice inconsistent with recommendations.