# Appendix References

1 Higgins JPT, Savović J, Page MJ, . Chapter 8: Assessing risk of bias in a randomized trial. In: Higgins JPT, Thomas J, Chandler J, Cumpston M, Li T, Page MJ, Welch VA (editors). Cochrane Handbook for Systematic Reviews of Interventions version 6.3 (updated February 2022). 2022. Available from: http://www.training.cochrane.org/handbook.
2 United States Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2021. Available from: https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes#methods.
3 Abbass-Dick J, Stern SB, Nelson LE, . Coparenting breastfeeding support and exclusive breastfeeding: a randomized controlled trial. Pediatrics. 2015;135(1):102–10. PMID: 254525653. 10.1542/peds.2014-1416 25452653
4 Abbass-Dick J, Sun W, Newport A, . The comparison of access to an eHealth resource to current practice on mother and co-parent teamwork and breastfeeding rates: A randomized controlled trial. Midwifery. 2020;90:102812. PMID: 32739716. 10.1016/j.midw.2020.102812 32739716
5 Acar Z and Sahin N. Development of a mobile application-based breastfeeding program and evaluation of its effectiveness. J Pediatr Nurs. 2024;74:51–60. PMID: 37995477. 10.1016/j.pedn.2023.11.011 37995477
6 Addicks SH and McNeil DW. Randomized Controlled Trial of Motivational Interviewing to Support Breastfeeding Among Appalachian Women. J Obstet Gynecol Neonatal Nurs. 2019;48(4):418–32. PMID: 31181186. 10.1016/j.jogn.2019.05.003 31181186
7 Anderson AK, Damio G, Young S, . A randomized trial assessing the efficacy of peer counseling on exclusive breastfeeding in a predominantly Latina low-income community. Arch Pediatr Adolesc Med. 2005;159(9):836–41. PMID: 16143742. 10.1001/archpedi.159.9.836 16143742
8 Balaguer Martinez J, Valcarce PI, Esquivel OJ, . Telephone support for breastfeeding by primary care: a randomised multicentre trial. Anales de pediatria (barcelona, spain : 2003). 2018;89(6):344–51. PMID: 29576447. 10.1016/j.anpedi.2018.02.007 29576447
9 Baransel ES and Caliskan BE. Effects of Face-to-Face Education Followed by Mobile Messaging to Primiparas on Maternal-Neonatal Care, Breastfeeding, and Motherhood Experience: A Randomized Controlled Trial. Z Geburtshilfe Neonatol. 2024;29:29. PMID: 38286412. 10.1055/a-2222-6568 38286412
10 Bender W, Levine L and Durnwald C. Text Message-Based Breastfeeding Support Compared With Usual Care: A Randomized Controlled Trial. Obstet Gynecol. 2022;140(5):853–60. PMID: 36201773. 10.1097/aog.0000000000004961 36201773
11 Bernal D. The effect of a peer counseling support program on breastfeeding initiation, duration and exclusivity among low-income Hispanic women. Doctoral clinical scholarly project. Brandman University; 2018.
12 Bonuck KA, Freeman K and Trombley M. Randomized controlled trial of a prenatal and postnatal lactation consultant intervention on infant health care use. Arch Pediatr Adolesc Med. 2006;160(9):953–60. PMID: 16953019. 10.1001/archpedi.160.9.953 16953019
13 Bonuck K, Stuebe A, Barnett J, . Effect of primary care intervention on breastfeeding duration and intensity (BINGO). Am J Public Health. 2014_a;104 Suppl 1:S119–27. PMID: 24354834. 10.2105/AJPH.2013.301360 24354834
14 Bonuck K, Stuebe A, Barnett J, . Effect of primary care intervention on breastfeeding duration and intensity (PAIRINGS). Am J Public Health. 2014_b;104 Suppl 1:S119–27. PMID: 24354834. 10.2105/AJPH.2013.301360 24354834
15 Bunik M, Shobe P, O’Connor ME, . Are 2 weeks of daily breastfeeding support insufficient to overcome the influences of formula? Acad Pediatr. 2010;10(1):21–8. PMID: 20129478. 10.1016/j.acap.2009.09.014 20129478
16 Bunik M, Jimenez-Zambrano A, Solano M, . Mother’s Milk Messaging TM: trial evaluation of app and texting for breastfeeding support. BMC Pregnancy Childbirth. 2022;22(1):660. PMID: 36002798. 10.1186/s12884-022-04976-6 36002798
17 Cangol E and Sahin NH. The Effect of a Breastfeeding Motivation Program Maintained During Pregnancy on Supporting Breastfeeding: A Randomized Controlled Trial. Breastfeed Med. 2017;12:218–26. PMID: 28287819. 10.1089/bfm.2016.0190 28287819
18 Carlsen EM, Kyhnaeb A, Renault KM, . Telephone-based support prolongs breastfeeding duration in obese women: a randomized trial. Am J Clin Nutr. 2013;95(2):1226–32. PMID: 24004897. 10.3945/ajcn.113.059600 24004897
19 Cauble JS, Herman A, Wick J, . A prenatal group based phone counseling intervention to improve breastfeeding rates and complementary feeding: a randomized, controlled pilot and feasibility trial. BMC Pregnancy Childbirth. 2021;21(1):521. PMID: 34294051. 10.1186/s12884-021-03976-2 34294051
20 Chan MY, Ip WY and Choi KC. The effect of a self-efficacy-based educational programme on maternal breast feeding self-efficacy, breast feeding duration and exclusive breast feeding rates: A longitudinal study. Midwifery. 2016;36:92–8. PMID: 27106949. 10.1016/j.midw.2016.03.003 27106949
21 Chapman DJ, Morel K, Bermudez-Millan A, . Breastfeeding education and support trial for overweight and obese women: a randomized trial. Pediatrics. 2013;131(1):e162–70. PMID: 23209111. 10.1542/peds.2012-0688 23209111
22 Clarke JL, Ingram J, Johnson D, . The ABA intervention for improving breastfeeding initiation and continuation: Feasibility study results. Matern Child Nutr. 2020;16(1):e12907. PMID: 31793233. 10.1111/mcn.12907 31793233
23 Dennis CL, Hodnett E, Gallop R, . The effect of peer support on breast-feeding duration among primiparous women: a randomized controlled trial. CMAJ. 2002;166(1):21–8. PMID: 11800243. None11800243
24 Di Meglio G, McDermott MP and Klein JD. A randomized controlled trial of telephone peer support’s influence on breastfeeding duration in adolescent mothers. Breastfeed Med. 2010;5(1):41–7. PMID: 20043705. 10.1089/bfm.2009.0016 20043705
25 Di Napoli A, Di Lallo D, Fortes C, . Home breastfeeding support by health professionals: findings of a randomized controlled trial in a population of Italian women. Acta Paediatr. 2004;93(8):1108–14. PMID: 15456204. None15456204
26 Edwards RC, Thullen MJ, Korfmacher J, . Breastfeeding and complementary food: randomized trial of community doula home visiting. Pediatrics. 2013;132 Suppl 2:S160–6. PMID: 24187119. 10.1542/peds.2013-1021P 24187119
27 Elliott-Rudder M, Pilotto L, McIntyre E, . Motivational interviewing improves exclusive breastfeeding in an Australian randomised controlled trial. Acta Paediatr. 2014;103(1):e11–6. PMID: 24117857. 10.1111/apa.12434 24117857
28 Fan HSL, Ho MY, Ko RWT, . Feasibility and effectiveness of WhatsApp online group on breastfeeding by peer counsellors: a single-blinded, open-label pilot randomized controlled study. Int Breastfeed J. 2022;17(1):91. PMID: 36544208. 10.1186/s13006-022-00535-z 36544208
29 Fiks AG, Gruver RS, Bishop-Gilyard CT, . A Social Media Peer Group for Mothers To Prevent Obesity from Infancy: The Grow2Gether Randomized Trial. Child. 2017;13(5):356–68. PMID: 28557558. 10.1089/chi.2017.0042 28557558
30 Forster D, McLachlan H, Lumley J, . Two mid-pregnancy interventions to increase the initiation and duration of breastfeeding: a randomized controlled trial. Birth. 2004;31(3):176–82. PMID: 15330879. 10.1111/j.0730-7659.2004.00302.x 15330879
31 Forster DA, McLardie-Hore FE, McLachlan HL, . Proactive Peer (Mother-to-Mother) Breastfeeding Support by Telephone (Ringing up About Breastfeeding Early [RUBY]): A Multicentre, Unblinded, Randomised Controlled Trial. EClinicalMedicine. 2019;8:20–8. PMID: 31193656. 10.1016/j.eclinm.2019.02.003 31193656
32 Franco-Antonio C, Calderon-Garcia JF, Santano-Mogena E, . Effectiveness of a brief motivational intervention to increase the breastfeeding duration in the first 6 months postpartum: Randomized controlled trial. J Adv Nurs. 2020;76(3):888–902. PMID: 31782535. 10.1111/jan.14274 31782535
33 Fu I, Fong D, Heys M, . Professional breastfeeding support for first-time mothers: a multicentre cluster randomised controlled trial. Bjog. 2014;121(13):1673–83. PMID: 24861802. 10.1111/1471-0528.12884 24861802
34 Gagnon AJ, Dougherty G, Jimenez V, . Randomized trial of postpartum care after hospital discharge. Pediatrics. 2002;109(6):1074–80. PMID: 12042545. 10.1542/peds.109.6.1074 12042545
35 Gijsbers B, Mesters I, Knottnerus JA, . The Success of an Educational Program to Promote Exclusive Breastfeeding for 6 Months in Families with a History of Asthma: A Randomized Controlled Trial. Pediatric Asthma, Allergy & Immunology. 2006;19(4):214–22. PMID: None. 10.1089/pai.2006.19.214
36 Graffy J, Taylor J, Williams A, . Randomised controlled trial of support from volunteer counsellors for mothers considering breast feeding. Bmj. 2004;328(7430):26. PMID: 14703543. 10.1136/bmj.328.7430.26 14703543
37 Gross RS, Mendelsohn AL, Gross MB, . Randomized Controlled Trial of a Primary Care-Based Child Obesity Prevention Intervention on Infant Feeding Practices. Journal of Pediatrics. 2016;174:171–7.e2. PMID: 27113376. 10.1016/j.jpeds.2016.03.060 27113376
38 Hans SL, Edwards RC and Zhang Y. Randomized Controlled Trial of Doula-Home-Visiting Services: Impact on Maternal and Infant Health. Maternal & Child Health Journal. 2018;22(Suppl 1):105–13. PMID: 29855838. 10.1007/s10995-018-2537-7 29855838
39 Henderson A, Stamp G and Pincombe J. Postpartum positioning and attachment education for increasing breastfeeding: a randomized trial. Birth. 2001;28(4):236–42. PMID: 11903211. 10.1046/j.1523-536x.2001.00236.x 11903211
40 Hoffmann J, Gunther J, Stecher L, . Effects of a lifestyle intervention in routine care on short-and long-term maternal weight retention and breastfeeding behavior - 12 months follow-up of the cluster-randomized gelis trial. J Clin Med. 2019; 8(6):876. 10.3390/jcm8060876 31248138
41 Hopkinson J and Konefal Gallagher M. Assignment to a hospital-based breastfeeding clinic and exclusive breastfeeding among immigrant Hispanic mothers: a randomized, controlled trial. J Hum Lact. 2009;25(3):287–96. PMID: 19436060. 10.1177/0890334409335482 19436060
42 Howell EA, Bodnar-Deren S, Balbierz A, . An intervention to extend breastfeeding among black and Latina mothers after delivery. Am J Obstet Gynecol. 2014;210(3):239.e1–5. PMID: 24262719. 10.1016/j.ajog.2013.11.028 24262719
43 Jolly K, Ingram L, Freemantle N, . Effect of a peer support service on breast-feeding continuation in the UK: A randomised controlled trial. Midwifery. 2012;28(6):740–5. PMID: 21944571. 10.1016/j.midw.2011.08.005 21944571
44 Karaahmet AY and Bilgic FS. Breastfeeding success in the first 6 months of online breastfeeding counseling after cesarean delivery and its effect on anthropometric measurements of the baby: a randomized controlled study. Rev Assoc Med Bras. 2022;68(10):1434–40. PMID: 36417649. 10.1590/1806-9282.20220540 36417649
45 Kellams AL, Gurka KK, Hornsby PP, . The Impact of a Prenatal Education Video on Rates of Breastfeeding Initiation and Exclusivity during the Newborn Hospital Stay in a Low-income Population. J Hum Lact. 2015. PMID: 26289058. 10.1177/0890334415599402 26289058
46 Kenyon S, Jolly K, Hemming K, . Lay support for pregnant women with social risk: a randomised controlled trial. BMJ Open. 2016;6(3):e009203. PMID: 26936901. 10.1136/bmjopen-2015-009203 26936901
47 Kools EJ, Thijs C, Kester AD, . A breast-feeding promotion and support program a randomized trial in The Netherlands. Prev Med. 2005;40(1):60–70. PMID: 15530582. 10.1016/j.ypmed.2004.05.013 15530582
48 Kronborg H, Maimburg RD and Vaeth M. Antenatal training to improve breast feeding: a randomised trial. Midwifery. 2012;28(6):784–90. PMID: 22018394. 10.1016/j.midw.2011.08.016 22018394
49 Labarere J, Bellin V, Fourny M, . Assessment of a structured in-hospital educational intervention addressing breastfeeding: a prospective randomised open trial. Bjog. 2003;110(9):847–52. PMID: 14511968. None14511968
50 Labarere J, Gelbert-Baudino N, Ayral AS, . Efficacy of breastfeeding support provided by trained clinicians during an early, routine, preventive visit: a prospective, randomized, open trial of 226 mother-infant pairs. Pediatrics. 2005;115(2):e139–e46. PMID: 15687421. 10.1542/peds.2004-1362 15687421
51 Laliberte C, Dunn S, Pound C, . A randomized controlled trial of innovative postpartum care model for mother-baby dyads. PLoS ONE. 2016;11(2) (no pagination). PMID: 26871448. 10.1371/journal.pone.0148520 26871448
52 Lavender T, Baker L, Smyth R, . Breastfeeding expectations versus reality: a cluster randomised controlled trial. Bjog. 2005;112(8):1047–53. PMID: 16045516. 10.1111/j.1471-0528.2005.00644.x 16045516
53 Lewkowitz AK, Lopez JD, Stein RI, . Effect of a Home-Based Lifestyle Intervention on Breastfeeding Initiation Among Socioeconomically Disadvantaged African American Women with Overweight or Obesity. Breastfeed Med. 2018;13(6):418–25. PMID: 29912571. 10.1089/bfm.2018.0006 29912571
54 Lewkowitz AK, Lopez JD, Carter EB, . Impact of a novel smartphone application on low-income, first-time mothers’ breastfeeding rates: a randomized controlled trial. Am J Obstet Gynecol MFM. 2020;2(3):100143. PMID: 33345878. 10.1016/j.ajogmf.2020.100143 33345878
55 Linares AM, Cartagena D and Rayens MK. Las Dos Cosas Versus Exclusive Breastfeeding: A Culturally and Linguistically Exploratory Intervention Study in Hispanic Mothers Living in Kentucky. Journal of Pediatric Health Care. 2019;33(6):e46–e56. PMID: 31655788. 10.1016/j.pedhc.2019.07.009 31655788
56 Little EE, Cioffi CC, Bain L, . An Infant Carrier Intervention and Breastfeeding Duration: A Randomized Controlled Trial. Pediatrics. 2021;148(1):07. PMID: 34193622. 10.1542/peds.2020-049717 34193622
57 Lucas R, Zhang Y, Walsh SJ, . Efficacy of a Breastfeeding Pain Self-Management Intervention: A Pilot Randomized Controlled Trial. Nursing Research. 2019;68(2):E1–E10. PMID: 30829925. 10.1097/NNR.0000000000000336 30829925
58 Lutenbacher M, Elkins T and Dietrich MS. Using Community Health Workers to Improve Health Outcomes in a Sample of Hispanic Women and Their Infants: Findings from a Randomized Controlled Trial. Hisp Health Care Int. 2023:21(3):129–141. PMID: 35702003. 10.1177/15404153221107680 35702003
59 Mattar CN, Chong YS, Chan YS, . Simple antenatal preparation to improve breastfeeding practice: a randomized controlled trial. Obstet Gynecol. 2007;109(1):73–80. PMID: 17197590. 10.1097/01.AOG.0000249613.15466.26 17197590
60 McDonald SJ, Henderson JJ, Faulkner S, . Effect of an extended midwifery postnatal support programme on the duration of breast feeding: a randomised controlled trial. Midwifery. 2010;26(1):88–100. PMID: 18486287. 10.1016/j.midw.2008.03.001 18486287
61 McLachlan HL, Forster DA, Amir LH, . Supporting breastfeeding In Local Communities (SILC) in Victoria, Australia: a cluster randomised controlled trial. BMJ Open. 2016;6(2):e008292. PMID: 26832427. 10.1136/bmjopen-2015-008292 26832427
62 McQueen KA, Dennis CL, Stremler R, . A pilot randomized controlled trial of a breastfeeding self-efficacy intervention with primiparous mothers. J Obstet Gynecol Neonatal Nurs. 2011;40(1):35–46. PMID: 21244493. 10.1111/j.1552-6909.2010.01210.x 21244493
63 Milinco M, Travan L, Cattaneo A, . Effectiveness of biological nurturing on early breastfeeding problems: a randomized controlled trial. Int Breastfeed J. 2020;15(1):21. PMID: 32248838. 10.1186/s13006-020-00261-4 32248838
64 Miremberg H, Yirmiya K, Rona S, . Smartphone-based counseling and support platform and the effect on postpartum lactation: a randomized controlled trial. Am J Obstet Gynecol MFM. 2022;4(2):100543. PMID: 34871782. 10.1016/j.ajogmf.2021.100543 34871782
65 Mottl-Santiago J, Dukhovny D, Cabral H, . Effectiveness of an Enhanced Community Doula Intervention in a Safety Net Setting: A Randomized Controlled Trial. Health Equity. 2023;7(1):466–76. PMID: 37731785. 10.1089/heq.2022.0200 37731785
66 Muirhead PE, Butcher G, Rankin J, . The effect of a programme of organised and supervised peer support on the initiation and duration of breastfeeding: a randomised trial. Br J Gen Pract. 2006;56(524):191–7. PMID: 16536959. None16536959
67 Nilsson IMS, Strandberg-Larsen K, Knight CH, . Focused breastfeeding counselling improves short- and long-term success in an early-discharge setting: A cluster-randomized study. Matern Child Nutr. 2017;13(4):10. PMID: 28194877. 10.1111/mcn.12432 28194877
68 Noel-Weiss J, Rupp A, Cragg B, . Randomized controlled trial to determine effects of prenatal breastfeeding workshop on maternal breastfeeding self-efficacy and breastfeeding duration. J Obstet Gynecol Neonatal Nurs. 2006;35(5):616–24. PMID: 16958717. 10.1111/j.1552-6909.2006.00077.x 16958717
69 O’Reilly SL, McNestry C, McGuinness D, . Multicomponent perinatal breastfeeding support in women with BMI >25: The Latch On multi-centre randomised trial. BJOG: An International Journal of Obstetrics & Gynaecology. 2024;12:12. PMID: 38344894. 10.1111/1471-0528.17782 38344894
70 Paul IM, Beiler JS, Schaefer EW, . A randomized trial of single home nursing visits vs office-based care after nursery/maternity discharge: the Nurses for Infants Through Teaching and Assessment After the Nursery (NITTANY) Study. Arch Pediatr Adolesc Med. 2012;166(3):263–70. PMID: 22064874. 10.1001/archpediatrics.2011.198 22064874
71 Pollard DL. Impact of a feeding log on breastfeeding duration and exclusivity. Matern Child Health J. 2011;15(3):395–400. PMID: 20177755. 10.1007/s10995-010-0583-x 20177755
72 Puharic D, Malicki M, Borovac JA, . The effect of a combined intervention on exclusive breastfeeding in primiparas: A randomised controlled trial. Matern Child Nutr. 2020;16(3):e12948. PMID: 31943761. 10.1111/mcn.12948 31943761
73 Quinlivan JA, Box H and Evans SF. Postnatal home visits in teenage mothers: a randomised controlled trial. Lancet. 2003;361(9361):893–900. PMID: 12648967. 10.1016/S0140-6736(03)12770-5 12648967
74 Reeder JA, Joyce T, Sibley K, . Telephone peer counseling of breastfeeding among WIC participants: a randomized controlled trial. Pediatrics. 2014;134(3):e700–9. PMID: 25092936. 10.1542/peds.2013-4146 25092936
75 Saglik M and Karacam Z. Effectiveness of structured education and follow-up in the management of perceived breastmilk insufficiency: a randomized control trial. Health Care Women Int. 2021:1–19. PMID: 34919025. 10.1080/07399332.2021.2007249 34919025
76 Santamaria-Martin MJ, Martin-Iglesias S, Schwarz C, . Effectiveness of a group educational intervention - prolact - in primary care to promote exclusive breastfeeding: a cluster randomized clinical trial. BMC Pregnancy Childbirth. 2022;22(1):132. PMID: 35172775. 10.1186/s12884-022-04394-8 35172775
77 Sari C and Altay N. Effects of providing nursing care with web-based program on maternal self-efficacy and infant health. Public Health Nurs. 2020;37(3):380–92. PMID: 32017251. 10.1111/phn.12712 32017251
78 Sari Ozturk C and Demir K. The Effect of Mandala Activity and Technology-Based Breastfeeding Program on Breastfeeding Self-Efficacy and Mother-Infant Attachment of Primiparous Women: A Randomized Controlled Study. J Med Syst. 2023;47(1):44. PMID: 37004692. 10.1007/s10916-023-01942-3 37004692
79 Saucedo Baza A, Mignacca C, Delgado PE, . A Technological Approach to Improved Breastfeeding Rates and Self-Efficacy: A Randomized Controlled Pilot Study. J Hum Lact. 2023;39(4):679–87. PMID: 37571838. 10.1177/08903344231190625 37571838
80 Schwarz EB, Hoyt-Austin A, Fix M, . Prenatal Counseling on the Maternal Health Benefits of Lactation: A Randomized Trial. Breastfeed Med. 2024;19(1):52–8. PMID: 38190278. 10.1089/bfm.2023.0219 38190278
81 Sevda KO and Sevil I. Continuous Lactation Support Provided Through the WhatsApp Messaging Application: A Randomized Controlled Trial. J Hum Lact. 2023;39(4):666–78. PMID: 37646262. 10.1177/08903344231192948 37646262
82 Simsek-Cetinkaya S, Gumus Calis G and Kibris S. Effect of Breastfeeding Education Program and Nurse-led Breastfeeding Online Counseling System (BMUM) for Mothers: A Randomized Controlled Study. J Hum Lact. 2024;40(1):101–12. PMID: 38006250. 10.1177/08903344231210813 38006250
83 Stockdale J, Sinclair M, Kernohan WG, . Feasibility study to test DESIGNER BREASTFEEDING: a randomised controlled trial. Evidence Based Midwifery. 2008;6(3):76–82. PMID: None. None
84 Su LL, Chong YS, Chan YH, . Antenatal education and postnatal support strategies for improving rates of exclusive breast feeding: randomised controlled trial. Bmj. 2007;335(7620):596. PMID: 17670909. 10.1136/bmj.39279.656343.55 17670909
85 Taylor B, Gray A, Galland B, . Targeting sleep, food, and activity in infants for obesity prevention: an RCT. Pediatrics. 2017;139(3) (no pagination). PMID: 28242860. 10.1542/peds.2016-2037 28242860
86 Uscher-Pines L, Ghosh-Dastidar B, Bogen DL, . Feasibility and Effectiveness of Telelactation Among Rural Breastfeeding Women. Academic pediatrics. 2020;20(5):652–9. PMID: 31629118. 10.1016/j.acap.2019.10.008 31629118
87 Wallace LM, Dunn OM, Alder EM, . A randomised-controlled trial in England of a postnatal midwifery intervention on breast-feeding duration. Midwifery. 2006;22(3):262–73. PMID: 16380197. 10.1016/j.midw.2005.06.004 16380197
88 Wambach KA, Aaronson L, Breedlove G, . A randomized controlled trial of breastfeeding support and education for adolescent mothers. West J Nurs Res. 2011;33(4):486–505. PMID: 20876551. 10.1177/0193945910380408 20876551
89 Wen LM, Baur LA, Simpson JM, . Effectiveness of an early intervention on infant feeding practices and “tummy time”: a randomized controlled trial. Arch Pediatr Adolesc Med. 2011;165(8):701–7. PMID: 21810633. 10.1001/archpediatrics.2011.115 21810633
90 Wen LM, Rissel C, Xu H, . Effects of Telephone and Short Message Service Support on Infant Feeding Practices, “Tummy Time,” and Screen Time at 6 and 12 Months of Child Age: A 3-Group Randomized Clinical Trial. JAMA Pediatrics. 2020;174(7):657–64. PMID: 32282034. 10.1001/jamapediatrics.2020.0215 32282034
91 Wong KL, Tak Fong DY, Yin Lee IL, . Antenatal education to increase exclusive breastfeeding: a randomized controlled trial. Obstet Gynecol. 2014;124(5):961–8. PMID: 25437725. 10.1097/AOG.0000000000000481 25437725
92 Yesil Y, Ekşioğlu A and Turfan EC. The effect of hospital-based breastfeeding group education given early perinatal period on breastfeeding self-efficacy and breastfeeding status. Journal of Neonatal Nursing. 2023;29(1):81–90. 10.1016/j.jnn.2022.02.013