# Appendix G Ongoing Studies

Study Name; Trial Identifier | Location | Estimated N | Description | Relevant Outcomes | 2025 Status
Furthering Equity Through Infant Feeding EDucation and Support (FEEDS); NCT05441709 (https://clinicaltrials.gov/ct2/show/NCT05441709?term=counseling%2C+support%2C+lactation&cond=breastfeeding&cntry=US&draw=2&rank=3) | Chicago, IL | 720 | The purpose of this study is to identify whether adding clinically integrated breastfeeding peer counseling (ci-BPC) to standard lactation care is associated with a reduction in disparities in breastfeeding intensity and duration for Black and Hispanic/Latine families. | Any breastfeeding duration, Exclusive breastfeeding | Estimated completion June 2026
A Technological Approach to Improved Breastfeeding Rates and Self-Efficacy: A Randomized Controlled Clinical Trial; NCT05673317 (https://clinicaltrials.gov/ct2/show/NCT05673317?term=counseling%2C+support%2C+lactation&cond=breastfeeding&cntry=US&draw=3&rank=11) | Augusta, GA | 40 | To provide patients with easily accessible information in the form of a smartphone application regarding medically appropriate information about breastfeeding and to assess the impact this information has on women’s breastfeeding rates and perception of self-efficacy (primary outcome). | Any breastfeeding | Completed, No results published
Navigating New Motherhood 2: Patient Navigation to Improve Outcomes Among Low-income Women in the Postpartum Period; NCT03922334 (https://clinicaltrials.gov/ct2/show/NCT03922334?term=counseling%2C+support%2C+lactation&cond=breastfeeding&cntry=US&draw=3&rank=16) | Chicago, IL | 400 | The primary aim of this study is to determine whether implementation of a postpartum patient navigation program improves health outcomes among low-income women. Patient navigation is a barrier focused, long-term patient-centered intervention that offers support for a defined set of health services. The intervention under investigation is a comprehensive postpartum patient navigator program. Women who are randomized to receive patient navigation will be compared with women who are randomized to receive usual care. Navigators will support women through 1 year postpartum. The NNM2 program will be grounded in understanding and addressing social determinants of health in order to promote self-efficacy, enhance access, and sustain long-term engagement. Participants will undergo surveys, interviews, and medical record review at 4-12 weeks and 11-13 months postpartum. The investigators will additionally conduct focus groups and surveys with clinical providers. | Any breastfeeding, Breastfeeding duration, Maternal depression, Quality of life | Estimated completion June 2025
Breastfeeding - a Good Start Together; NCT05311631 (https://clinicaltrials.gov/study/NCT05311631?cond=NCT05311631&rank=1) | Copenhagen, Denmark | 5010 | The intervention consists of theory based breastfeeding support, supported by printed materials and a web page providing support and knowledge for families when health visitors are off work, and an intensified intervention aimed at the high-risk group, comprising close followup by telephone and an extra home visit. In total, the high-risk group will receive seven telephone calls during week two postpartum and 15 weeks postpartum, with the highest intensity in the first month (contact once a week), gradually decreasing as the child grows older (contact every second week during the second month, and every third week during the third and fourth month). | Breastfeeding (full/not full), Breastfeeding problems | Estimated completion December 2025
PRenatal Video-Based Education and PostPARtum Effects (PREPARE); NCT04258709 (https://clinicaltrials.gov/study/NCT04258709?cond=NCT04258709&rank=1) | Pittsburgh, PA | 280 | The purpose of this randomized controlled trial is to examine the impact of a remotely-delivered antenatal milk expression intervention versus an attention control condition on breastfeeding outcomes among a sample of 280 nulliparous, non-diabetic women with pre-pregnancy body mass indices ≥ 25. | Any breastfeeding, Exclusive breastfeeding | Estimated completion March 2025
MILC: A Comprehensive Mobile Application That Addresses the Breastfeeding Challenges of Low-income Hispanic Mothers (MILC); NCT06520696 (https://clinicaltrials.gov/study/NCT06520696?cond=NCT06520696&rank=1) | Multisite, USA | 178 | The innovative platform MILC is designed to provide an integrated and comprehensive professional and social support network with personalized breastfeeding education to target exclusive breastfeeding and any BF behaviors in low-income Hispanic women. | Any breastfeeding, Exclusive breastfeeding, Maternal depression | Estimated completion June 2025
Father-involvement Telephone Support Intervention on Breastfeeding; NCT05109988 (https://clinicaltrials.gov/study/NCT05109988?cond=NCT05109988&rank=1) | Hong Kong | 738 | The objectives of this study are to evaluate the effect of a father-involvement breastfeeding telephone support intervention on prevalence and duration of exclusive breastfeeding, postnatal depression, and parent-infant bonding. The intervention consists of four weekly 20-30 minutes telephone-administered counselling sessions on breastfeeding, delivered individually in the first month postpartum for mothers and fathers. We expect that women who receive the intervention will have a higher rate and longer duration of exclusive breastfeeding, fewer depressive symptoms and better parent-child relationship. | Exclusive breastfeeding, Maternal depression | Estimated completion January 2025 No results published
Client-Centered Breastfeeding Support: Effects on Primipara Mothers in a Randomized Trial Breastfeeding Self-Efficacy, Attitudes, and Problems in Primiparous Mothers: A Randomized Controlled Trial; NCT06446362 (https://clinicaltrials.gov/study/NCT06446362?cond=NCT06446362&rank=1) | Türkiye | 45 | The primary aim of this study is to investigate the impact of a breastfeeding support program, based on a client health behavior interaction model, on the breastfeeding self-efficacy, attitudes, and problems of first-time mothers. | Exclusive breastfeeding, Breastfeeding problems | Estimated completion December 2026