# Appendix F Implementation Table: Summary and Examples of Included Interventions

Primary Population | Pregnant and lactating adolescents and adults
Primary Outcomes Measured | Prevalence of any and exclusive breastfeeding initiation and up to infant age of 6 months
Study Findings | There was a statistically significant association between participating in a breastfeeding support intervention versus usual care and the prevalence of any and exclusive breastfeeding at <3 months, 3 to <6 months, and 6 months. There was an impact on exclusive, but not any, breastfeeding initiation. Few studies reported the prevalence of breastfeeding at 1 year.
Behavior change goals and techniques | Most studies were designed to help participants improve self-efficacy to breastfeed and to address common challenges and problems associated with breastfeeding. Content typically focused on the importance of breastfeeding, how to breastfeed, common concerns, and how to get help. Many interventions included didactic education in addition to individualized encouragement and practical and material support. Skills were taught through observed, direct practice of breastfeeding. Many interventions offered a “warm line” telephone support for participants to access as needed. Several interventions included postpartum home visits.; A small number of interventions focused specifically on infant positioning while breastfeeding, providing ergonomic carriers to facilitate physical contact, and self-monitoring of breastfeeding sessions. Few emphasized the involvement of coparents or support persons.
Duration of interventions | Varied widely from 1 day (1 session) to >1 year of support. Most interventions consisted of six or fewer sessions (median=4).
Settings of Studies | Prenatal and pediatric clinics, hospitals, and homes; 37% took place in the United States.
To Whom is Intervention Targeted? | Pregnant and lactating persons ranging in age from 16 to 33 years who were mostly intending to breastfeed.
INTERVENTION TYPE | Professional-Led Support | Peer-Led Support | Formal or Structured Education | Remotely Delivered Support
Mode and intensity of delivery | Most professional support was provided at and around the time of delivery and postpartum. Intensity of support was highly variable and ranged from one 30-minute in-hospital session to a very intense intervention where women received 20 weeks of support from both a physician or midwife and an IBCLC during seven in-person prenatal sessions, up to 12 postpartum telephone calls, an optional postpartum home visit. Most interventions were 4 sessions or less. | Highly variable in terms of duration and number of sessions. Most had contact in prenatal and postpartum periods and consisted of several home visits and telephone support. In all cases, peer counselors were recruited specifically for the study: they were chosen to represent the sample population (e.g., adolescents, WIC recipients, Hispanic women) and had previous breastfeeding experience. | In-person individual and group prenatal education during 1 session ranging from 15 minutes to 3 hours. Few included educational videos.; 60 daily text messages offering professional advice to address specific issues of breastfeeding depending on stage of pregnancy/postpartum. | Included app-based breastfeeding education and support, peer and professional telephone support, group-based telephone support, text message breastfeeding information and support, and web-based education. Duration of these interventions was typically longer and most included support during the postpartum period.
Example interventions^*^,^†^ | Addicks, 2019^1^; Bonuck, 2006^2^; Bonuck, 2014a (BINGO)^3,**^; Bonuck, 2014b (PAIRINGS)^4,**^; Hopkinson, 2009^5,**^; Little, 2021^6^ | Anderson, 2005^7^; Chapman, 2013^8^; Linares, 2019^9^ (Las Dos Cosas); Lutenbacher, 2022^10,**^; Wambach, 2011^11^ | Bunik, 2022^12^; Kellams, 2015^13,**^ | Bender, 2022^14,**^; Bernal, 2019^15^ Bunik, 2010^16^; Cauble, 2021^17,**^; Di Meglio, 2010^18^; Lewkowitz, 2020^19,**^; Lucas, 2019^20^; Pollard, 2011^21,**^; Reeder, 2014^22^; Uscher-Pines, 2020^23,**^ (Tele-MILC)
Materials Provided for Practice (Materials for specific cited programs)^§^ | Intervention descriptions provided in individual trials; no materials provided for practice.; Bonuck et al. summarize intervention development and translation in a publication titled “Clinical Translational Research Hits the Road”^24^ | Intervention descriptions provided in individual trials; no materials provided for practice.; Training for peer counselors used the Peer Counseling Training for WIC Managers from the U.S. Department of Agriculture;^25^ Breastfeeding: Heritage and Pride: A Manual for the Training of Breastfeeding Peer Counselors in the Puerto Rican Community;^26,^ ^27^ the Breastfeeding Peer Counselor Program Curriculum from the La Leche League;^28^ the World Health Organization/United Nations Children’s Fund Breastfeeding Counseling Training Course;^29^ the Maternal Infant Health Outreach Worker (MIHOW) “strengths perspectives” program materials^30^ | 25-minute educational breastfeeding video titled “Better Breastfeeding” (Injoy Productions, 2008)^31^; 100 text messages initially developed by the study team and reduced to 60 messages based on pilot testing among pregnant and postpartum persons.^32^ | Intervention descriptions provided in individual trials; no materials provided for practice.; Two trials tested publicly available apps: the BreastFeeding Friend app,^33^ and Pacify Health’s telelactation app^34^
Evidence of effect modification | No pattern of effects was seen based on population characteristics (maternal age, intention to breastfeed, primiparity status, country) or intervention characteristics (timing of intervention, type of intervention, duration, number of sessions, and in-person vs. remote delivery).
Comparison group | Usual prenatal, peripartum, and postpartum care. Description of lactation support was rarely described.
Interventionist and Training Required | Most interventions were provided by highly trained professionals such as nurses, midwives, physicians, lactation care providers, and/or trained lay persons or peer counselors. Few studies noted certification of lactation care providers through the IBCLC or held some other lactation support certification.

Abbreviations: IBCLC = International Board-Certified Lactation Consultants.

* Example interventions only include those that took place in the United States.

† Inclusion of studies and materials are for example purposes only and does not indicate endorsement by the USPSTF.

** Good quality.

§ Materials provided for practice include materials or protocols that were noted within the source study and that we were able to locate.

## Appendix F References

1 Addicks SH, McNeil DW. Randomized Controlled Trial of Motivational Interviewing to Support Breastfeeding Among Appalachian Women. J Obstet Gynecol Neonatal Nurs. 2019;48(4):418–32. PMID: 31181186. 10.1016/j.jogn.2019.05.003 31181186
2 Bonuck KA, Freeman K, Trombley M. Randomized controlled trial of a prenatal and postnatal lactation consultant intervention on infant health care use. Arch Pediatr Adolesc Med. 2006;160(9):953–60. PMID: 16953019.16953019
3 Bonuck K, Stuebe A, Barnett J, . Effect of primary care intervention on breastfeeding duration and intensity (BINGO). Am J Public Health. 2014_a;104 Suppl 1:S119–27. PMID: 24354834. 10.2105/AJPH.2013.301360 24354834
4 Bonuck K, Stuebe A, Barnett J, . Effect of primary care intervention on breastfeeding duration and intensity (PAIRINGS). Am J Public Health. 2014_b;104 Suppl 1:S119–27. PMID: 24354834. 10.2105/AJPH.2013.301360 24354834
5 Hopkinson J, Konefal Gallagher M. Assignment to a hospital-based breastfeeding clinic and exclusive breastfeeding among immigrant Hispanic mothers: a randomized, controlled trial. J Hum Lact. 2009;25(3):287–96. PMID: 19436060. 10.1177/0890334409335482 19436060
6 Little EE, Cioffi CC, Bain L, . An Infant Carrier Intervention and Breastfeeding Duration: A Randomized Controlled Trial. Pediatrics. 2021;148(1):07. PMID: 34193622. 10.1542/peds.2020-049717 34193622
7 Anderson AK, Damio G, Young S, . A randomized trial assessing the efficacy of peer counseling on exclusive breastfeeding in a predominantly Latina low-income community. Arch Pediatr Adolesc Med. 2005;159(9):836–41. PMID: 16143742.16143742
8 Chapman DJ, Morel K, Bermudez-Millan A, . Breastfeeding education and support trial for overweight and obese women: a randomized trial. Pediatrics. 2013;131(1):e162–70. PMID: 23209111. 10.1542/peds.2012-0688 23209111
9 Linares AM, Cartagena D, Rayens MK. Las Dos Cosas Versus Exclusive Breastfeeding: A Culturally and Linguistically Exploratory Intervention Study in Hispanic Mothers Living in Kentucky. Journal of Pediatric Health Care. 2019;33(6):e46–e56. PMID: 31655788. 10.1016/j.pedhc.2019.07.009 31655788
10 Lutenbacher M, Elkins T, Dietrich MS. Using Community Health Workers to Improve Health Outcomes in a Sample of Hispanic Women and Their Infants: Findings from a Randomized Controlled Trial. Hisp Health Care Int. 2023;21(3):129–141. PMID: 35702003. 10.1177/15404153221107680 35702003
11 Wambach KA, Aaronson L, Breedlove G, . A randomized controlled trial of breastfeeding support and education for adolescent mothers. West J Nurs Res. 2011;33(4):486–505. PMID: 20876551. 10.1177/0193945910380408 20876551
12 Bunik M, Jimenez-Zambrano A, Solano M, . Mother’s Milk Messaging TM: trial evaluation of app and texting for breastfeeding support. BMC Pregnancy Childbirth. 2022;22(1):660. PMID: 36002798. 10.1186/s12884-022-04976-6 36002798
13 Kellams AL, Gurka KK, Hornsby PP, . The Impact of a Prenatal Education Video on Rates of Breastfeeding Initiation and Exclusivity during the Newborn Hospital Stay in a Low-income Population. J Hum Lact. 2015. PMID: 26289058. 10.1177/0890334415599402 26289058
14 Bender W, Levine L, Durnwald C. Text Message-Based Breastfeeding Support Compared With Usual Care: A Randomized Controlled Trial. Obstet Gynecol. 2022;140(5):853–60. PMID: 36201773. 10.1097/aog.0000000000004961 36201773
15 Bernal D. The effect of a peer counseling support program on breastfeeding initiation, duration and exclusivity among low-income Hispanic women. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2019;80(2-B(E)).
16 Bunik M, Shobe P, O’Connor ME, . Are 2 weeks of daily breastfeeding support insufficient to overcome the influences of formula? Acad Pediatr. 2010;10(1):21–8. PMID: 20129478. 10.1016/j.acap.2009.09.014 20129478
17 Cauble JS, Herman A, Wick J, . A prenatal group based phone counseling intervention to improve breastfeeding rates and complementary feeding: a randomized, controlled pilot and feasibility trial. BMC Pregnancy Childbirth. 2021;21(1):521. PMID: 34294051. 10.1186/s12884-021-03976-2 34294051
18 Di Meglio G, McDermott MP, Klein JD. A randomized controlled trial of telephone peer support’s influence on breastfeeding duration in adolescent mothers. Breastfeed Med. 2010;5(1):41–7. PMID: 20043705. 10.1089/bfm.2009.0016 20043705
19 Lewkowitz AK, Lopez JD, Carter EB, . Impact of a novel smartphone application on low-income, first-time mothers’ breastfeeding rates: a randomized controlled trial. Am J Obstet Gynecol MFM. 2020;2(3):100143. PMID: 33345878. 10.1016/j.ajogmf.2020.100143 33345878
20 Lucas R, Zhang Y, Walsh SJ, . Efficacy of a Breastfeeding Pain Self-Management Intervention: A Pilot Randomized Controlled Trial. Nursing Research. 2019;68(2):E1–E10. PMID: 30829925. 10.1097/NNR.0000000000000336 30829925
21 Pollard DL. Impact of a feeding log on breastfeeding duration and exclusivity. Matern Child Health J. 2011;15(3):395–400. PMID: 20177755. 10.1007/s10995-010-0583-x 20177755
22 Reeder JA, Joyce T, Sibley K, . Telephone peer counseling of breastfeeding among WIC participants: a randomized controlled trial. Pediatrics. 2014;134(3):e700–9. PMID: 25092936. 10.1542/peds.2013-4146 25092936
23 Uscher-Pines L, Ghosh-Dastidar B, Bogen DL, . Feasibility and Effectiveness of Telelactation Among Rural Breastfeeding Women. Academic pediatrics. 2020;20(5):652–9. PMID: 31629118. 10.1016/j.acap.2019.10.008 31629118
24 Bonuck KA, Lischewski J, Brittner M. Clinical translational research hits the road: RCT of breastfeeding promotion interventions in routine prenatal care. Contemp Clin Trials. 2009;30(5):419–26. PMID: 19523539. 10.1016/j.cct.2009.05.005 19523539
25 US Department of Agriculture. Peer Counseling Training for WIC Managers. https://wicworks.fns.usda.gov/resources/peer-counseling-training-wic-managers. Accessed: May 2023.
26 Hispanic Health Council. Breastfeeding: Heritage and Pride: A Manual for the Training of Breastfeeding Peer Counselors in the Puerto Rican Community. Hartford, Conn.: Hispanic Health Council; 2005. PMID.
27 Damio G, Hill N, Lebron E. Breastfeeding Heritage and Pride. Hartford, Conn.: Hispanic Health Council; 1995. PMID.
28 La Leche League International. Breastfeeding Peer Counselor Program, Curriculum, Revised Edition. Schaumberg, IL: La Leche League International; 2005.
29 World Health Organization/United Nations Children’s Fund. Breastfeeding Counseling: A Training Course. Geneva, Switzerland: WHO/UNICEF; 1993.
30 Graeme S. What is the Strengths Perspective? https://sustainingcommunity.wordpress.com/2012/05/30/what-is-the-strengths-perspective/. Accessed: 2023.
31 InJoy Videos. Better Breastfeeding: Your Guide to a Healthy Start. https://emro.libraries.psu.edu/record/index.php?id=3208. Accessed: May 2023.
32 Maya Bunik, Jenn Leiferman JRR, Anna Furniss, ., editors. Mother’s Milk Messaging (MMM): A Pilot Study of an App to Support Breastfeeding in First Time Mothers. American Academy of Pediatrics National Conference and Exhibition; 2015. PMID.
33 Leite A. BreastFeeding Friend. https://apps.apple.com/us/app/breastfeeding-friend/id691337566. Accessed: May 2023.
34 Pacify Health. Telelactation App. https://www.pacify.com/how-it-works/#:~:text=Pacify%20is%20a%20mobile%20app,%2D%20no%20appointments%2C%20no%20waiting. Accessed: May 2023.