# Appendix E Intervention Details and Evidence Tables

Appendix E Table 1 Detailed Intervention and Control Group Descriptions, by Author

Appendix E Table 2 Results of Breastfeeding Support Interventions on Prevalence of Any and Exclusive Breastfeeding, by Author

Appendix E Table 3 Results of Breastfeeding Support Interventions on Any and Exclusive Breastfeeding Duration and Breastfeeding Intensity, by Author

Appendix E Table 4 Number Needed to Treat for Any and Exclusive Breastfeeding for Varying Levels of Usual Breastfeeding Rates