# Appendix D Excluded Studies List

Exclusion Codes

E1. Study relevance (not related to breastfeeding intervention)
E2a. Setting: Not in very high human development country
E2b. Setting: Not linked to health care (e.g., worksites, correctional facilities)
E3a. Study design: Not an RCT
E3b. Study design: Not an included control group (e.g., comparative effectiveness)
E4a. Population: Studies of preterm or very preterm infants (<35 wks) or low or very low birth weight infants (<2,500 g)
E4b. Population: Studies limited to special populations of women or infants (e.g., institutionalized persons, infants with prenatal disease, infants in a NICU)
E5. Outcomes: No relevant outcomes (maternal or infant health outcomes; breastfeeding initiation, duration, exclusivity; or adverse events)
E6a. Intervention: Intervention otherwise out-of-scope (e.g., media campaign, community-wide program)
E6b. Intervention: Health system-level intervention or policy
E6c. Intervention: Skin-to-skin contact protocol
E6d. Intervention: Pacifier provision protocol
E7. Quality: Poor quality study
E7a. Parent study excluded for poor quality
E8. Publication Type: Editorial, conference presentation

1 Cash incentives may encourage breastfeeding rates early on. Nurs Child Young People. 30(1): 12–12. 2018. 10.7748/ncyp.30.01.12.s9. KQ1E8, KQ2E8, KQ3E8
2 ERRATUM. Zhao Y., Lin Q., Wang J. An evaluation of a prenatal individualised mixed management intervention addressing breastfeeding outcomes and postpartum depression: A randomised controlled trial. Journal of Clinical Nursing, 30 (9–10), 1347–1359. . 30: 2107–2107. 2021. 10.1111/jocn.15855. KQ1E8, KQ2E8, KQ3E833528901
3 Abbott, JL, Carty, JR, . Effect of Follow-Up Intervals on Breastfeeding Rates 5-6 Months Postpartum: A Randomized Controlled Trial. Breastfeeding Medicine: The Official Journal of the Academy of Breastfeeding Medicine. 14(1): 22–32. 2019. PMID: 30412416. 10.1089/bfm.2018.0071. KQ1E3b, KQ2E3b, KQ3E3b30412416
4 Ahmed, AH, Roumani, AM, . The Effect of Interactive Web-Based Monitoring on Breastfeeding Exclusivity, Intensity, and Duration in Healthy, Term Infants After Hospital Discharge. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. 45(2): 143–54. 2016. 10.1016/j.jogn.2015.12.001. KQ1E7, KQ2E7, KQ3E5
5 Akyildiz, D, Bay, B. The effect of breastfeeding support provided by video call on postpartum anxiety, breastfeeding self-efficacy, and newborn outcomes: A randomized controlled study. Japan Journal of Nursing Science: JJNS. 20(1): e12509. 2023. PMID: 36071624. 10.1111/jjns.12509. KQ1E7, KQ2E5, KQ3E736071624
6 Aldana-Parra, F, Olaya, G, . Effectiveness of a new breastfeeding counselling intervention on breastfeeding prevalence, infant growth velocity and postpartum weight loss in overweight women: a randomized controlled trial. J Pediatr Gastroenterol Nutr. 74: 976–977. 2022. 10.1097/MPG.0000000000003446. KQ1E2a, KQ2E2a, KQ3E2a
7 Alghamdi, S, Horodynski, M, . Racial and ethnic differences in breastfeeding, maternal knowledge, and self-efficacy among low-income mothers. Applied Nursing Research. 37: 24–27. 2017. PMID: 28985916. 10.1016/j.apnr.2017.07.009. KQ1E3a, KQ2E3a, KQ3E3a28985916
8 Anokye, N, Coyle, K, . Cost-effectiveness of offering an area-level financial incentive on breast feeding: a within-cluster randomised controlled trial analysis. Arch Dis Child. 105(2): 155–159. 2020. PMID: 31444210. 10.1136/archdischild-2018-316741. KQ1E6a, KQ2E6a, KQ3E6a31444210
9 Antonanzas-Baztan, E, Belintxon, M, . Six-month breastfeeding maintenance after a self-efficacy promoting programme: an exploratory trial. Scand J Caring Sci. 35(2): 548–558. 2021. PMID: 32400032. 10.1111/scs.12870. KQ1E3a, KQ2E3a, KQ3E3a32400032
10 Antoñanzas-Baztán, Elena, Belintxon, Maider, . Six-month breastfeeding maintenance after a self-efficacy promoting programme: an exploratory trial. Scand J Caring Sci. 35(2): 548–558. 2021. 10.1111/scs.12870. KQ1E3a, KQ2E3a, KQ3E3a32400032
11 Azimi, N, Nasiri, A. The effect of peer counseling on breastfeeding behavior of primiparous mothers: A randomized controlled field trial. Public Health Nurs. 37(3): 446–452. 2020. PMID: 31950527. 10.1111/phn.12692. KQ1E2a, KQ2E2a, KQ3E2a31950527
12 Ball, HL, Howel, D, . Bed-sharing by breastfeeding mothers: who bed-shares and what is the relationship with breastfeeding duration?. Acta Paediatr. 105(6): 628–34. 2016. PMID: 26848117. 10.1111/apa.13354. KQ1E3a, KQ2E3a, KQ3E3a26848117
13 Bond, DM, Shand, AW, . Breastfeeding patterns and effects of minimal supplementation on breastfeeding exclusivity and duration in term infants: A prospective sub-study of a randomised controlled trial. J Paediatr Child Health. 57(8): 1288–1295. 2021. PMID: 33768643. 10.1111/jpc.15464. KQ1E3a, KQ2E3a, KQ3E3a33768643
14 Bunik, Me, Jimenez-Zambrano, A, . Mother’s milk messagingTM (MMM): mixed methods evaluation of bilingual app and texting program to support breastfeeding (BF). Pediatrics. 147(3): 324–325. 2021. 10.1542/peds.147.3_MeetingAbstract.324. KQ1E8, KQ2E8, KQ3E8
15 Buultjens, Melissa, Murphy, Gregory, . Supporting the transition to parenthood: Development of a group health-promoting programme. British Journal of Midwifery. 26(6): 387–397. 2018. 10.12968/bjom.2018.26.6.387. KQ1E3a, KQ2E3a, KQ3E3a
16 Callaghan, S, Geraghty, AA, . Exploration of Factors Associated with Intention, Initiation and Duration of Breastfeeding. Ir Med J. 113(7): 124. 2020. PMID: 35575604. KQ1E3a, KQ2E3a, KQ3E3a35575604
17 Carfoot, S, Williamson, P, . A randomised controlled trial in the north of England examining the effects of skin-to-skin care on breast feeding. Midwifery. 21(1): 71–79. 2005. PMID: 15740818. 10.1016/j.midw.2004.09.002. KQ1E6c, KQ2E6c, KQ3E6c15740818
18 Cercer, Z, Nazik, Dr E. The effects of the breastfeeding problems management model on breastfeeding problems, breastfeeding motivation and breastfeeding success: A randomized controlled trial. J Pediatr Nurs. 73: e116–e124. 2023. PMID: 37550129. 10.1016/j.pedn.2023.07.021. KQ1E5, KQ2E5, KQ3E537550129
19 Chang, M-W, Nitzke, S, . Recruitment challenges and enrollment observations from a community based intervention (Mothers In Motion) for low-income overweight and obese women. Contemporary clinical trials communications. 5: 26–33. 2017. PMID: CN-01474305. 10.1016/j.conctc.2016.11.004. KQ1E1, KQ2E1, KQ3E128685168
20 Chaves, AFL, Ximenes, LB, . Telephone intervention in the promotion of self-efficacy, duration and exclusivity of breastfeeding: randomized controlled trial. Rev Lat Am Enfermagem. 27: e3140. 2019. PMID: 31038634. 10.1590/1518-8345.2777-3140. KQ1E2a, KQ2E2a, KQ3E2a31038634
21 Chegeni, Mitra Fathi, Valizadeh, Fatemeh, . Comparison of Different Virtual Follow-ups on Mother’s Lactation. Journal for Nurse Practitioners. 18(9): 988–994. 2022. 10.1016/j.nurpra.2022.08.005. KQ1E2a, KQ2E2a, KQ3E2a
22 Chehreh, R, Zahrani, ST, . Effect of peer support on breastfeeding self-efficacy in ilamian primiparous women: A single-blind randomized clinical trial. Journal of Family Medicine & Primary Care. 10(9): 3417–3423. 2021. PMID: 34760767. 10.4103/jfmpc.jfmpc_172_21. KQ1E2a, KQ2E2a, KQ3E2a34760767
23 Citil Canbay, Funda, Citil, Elif Tugce, . The effect of breastfeeding education and skin-to-skin contact on breastfeeding efficiency and maternal attachment: A randomized controlled study. Early Child Dev Care. No Pagination Specified. 2024. 10.1080/03004430.2024.2320885. KQ1E5, KQ2E5, KQ3E5
24 Clarke, Jl, Ingram, J, . An assets-based intervention before and after birth to improve breastfeeding initiation and continuation: the ABA feasibility RCT. Public health research. 8(7). 2020. PMID: 32320172. 10.3310/phr08070. KQ1E5, KQ2E7, KQ3E532320172
25 Cloutier, MM, Wiley, J, . The Early Childhood Obesity Prevention Program (ECHO): an ecologically-based intervention delivered by home visitors for newborns and their mothers. BMC Public Health. 15: 584. 2015. PMID: 26104068. 10.1186/s12889-015-1897-9. KQ1E7a, KQ2E7a, KQ3E7a26104068
26 Cloutier, Mm, Wiley, Jf, . Outcomes of an early childhood obesity prevention program in a low-income community: a pilot, randomized trial. Pediatr Obes. (no pagination). 2018. 10.1111/ijpo.12458. KQ1E7a, KQ2E7a, KQ3E7a
27 Cloutier, MM, Wiley, JF, . Outcomes of an early childhood obesity prevention program in a low-income community: a pilot, randomized trial. Pediatr Obes. 13(11): 677–685. 2018. PMID: 132626184. 10.1111/ijpo.12458. KQ1E7, KQ2E7, KQ3E530156058
28 Comerford, DavidA, McGillivray, Tracy. Effect of obstacles/tips card on breastfeeding drop-off. British Journal of Midwifery. 29(9): 510–515. 2021. 10.12968/bjom.2021.29.9.510. KQ1E3a, KQ2E3a, KQ3E3a
29 Cooijmans, KellyHM, Beijers, Roseriet, . Daily skin-to-skin contact in full-term infants and breastfeeding: Secondary outcomes from a randomized controlled trial. Matern Child Nutr. 18(1): 1–10. 2022. PMID: 154314742. 10.1111/mcn.13241. KQ1E6c, KQ2E6c, KQ3E6c
30 Cui, R, Wang, E. The effect of postpartum family visits on the promotion of breastfeeding and improvement of maternal and infant health. Am J Transl Res. 13(12): 14089–14095. 2021. PMID: 35035752. KQ1E2a, KQ2E2a, KQ3E2a35035752
31 da, Silva Cf, Nunes, Lm, . Effect of a pro-breastfeeding intervention on the maintenance of breastfeeding for 2 years or more: randomized clinical trial with adolescent mothers and grandmothers. BMC Pregnancy Childbirth. 16(1) (no pagination). 2016. 10.1186/s12884-016-0878-z. KQ1E2a, KQ2E2a, KQ3E2a
32 Dagli, E, Topkara, FN. The effect of tele-education delivered to mothers during the COVID-19 pandemic on breastfeeding success and perceived breastfeeding self-efficacy: Randomized controlled longitudinal trial. Health Care Women Int. 44(3): 345–360. 2023. PMID: 36227641. 10.1080/07399332.2022.2132251. KQ1E5, KQ2E5, KQ3E536227641
33 Dai, Hongxia. Influence of self - made breastfeeding manual combined with postpartum telephone guidance on infant feeding attitude of maternal. Chinese nursing research. 29(6b): 2079–2082. 2015. . KQ1E8, KQ2E8, KQ3E8
34 Davis, KE, Klingenberg, A, . The Baby Bites Text Messaging Project with randomized controlled trial: texting to improve infant feeding practices. Began with 2015. 9: 11. 2023. PMID: 37089270. 10.21037/mhealth-22-31. KQ1E5, KQ2E7, KQ3E537089270
35 DC Berry, M Neal, EG Hall, TA Schwartz, . Rationale, design, and methodology for the optimizing outcomes in women with gestational diabetes mellitus and their infants study. BMC Pregnancy Childbirth. 13. 2013. PMID: 24112417. 10.1186/1471-2393-13-184. KQ1E7a, KQ2E7a, KQ3E7a24112417
36 Demirci, JR, Glasser, M, . Structured antenatal milk expression education for nulliparous pregnant people: results of a pilot, randomized controlled trial in the United States. Int Breastfeed J. 17(1): 50. 2022. PMID: 35799299. 10.1186/s13006-022-00491-8. KQ1E6a, KQ2E6a, KQ3E6a35799299
37 Demirci, JR, Suffoletto, B, . The Development and Evaluation of a Text Message Program to Prevent Perceived Insufficient Milk Among First-Time Mothers: Retrospective Analysis of a Randomized Controlled Trial. JMIR MHealth and UHealth. 8(4): e17328. 2020. PMID: 32347815. 10.2196/17328. KQ1E5, KQ2E5, KQ3E532347815
38 Dodt, Regina Claudia Melo, Joventino, Emanuella Silva, . An experimental study of an educational intervention to promote maternal self-efficacy in breastfeeding. Rev Lat Am Enfermagem. 23(4): 725–732. 2015. 10.1590/0104-1169.0295.2609. KQ1E2a, KQ2E2a, KQ3E2a26444176
39 Drennan, Vari. Study analyses effect of financial incentive on breastfeeding rates. Primary Health Care. 28(4): 13–13. 2018. 10.7748/phc.28.4.13.s12. KQ1E8, KQ2E8, KQ3E8
40 E Owen-Jones, MJ Bekkers, CC Butler, R Cannings-John, . The effectiveness and cost-effectiveness of the Family Nurse Partnership home visiting programme for first time teenage mothers in England: a protocol for the Building Blocks randomised controlled trial. BMC Pediatr. 13. 2013. PMID: 23919573. 10.1186/1471-2431-13-114. KQ1E1, KQ2E1, KQ3E123919573
41 E Roby, EB Miller, DS Shaw, P Morris, . Improving Parent-Child Interactions in Pediatric Health Care: A Two-Site Randomized Controlled Trial. Pediatrics. 147(3). 2021. PMID: 33608413. 10.1542/peds.2020-1799. KQ1E1, KQ2E1, KQ3E133608413
42 Efrat, Mw, Esparza, S, . The effect of lactation educators implementing a telephone-based intervention among low-income Hispanics: a randomised trial. Health Educ J. 74(4): 424–441. 2015. 10.1177/0017896914542666. KQ1E5, KQ2E7, KQ3E526941454
43 Ekambareshwar, M, Taki, S, . Trial collaborators’ perceptions of the process of delivering Healthy Beginnings advice via telephone calls or text messages. Health Promotion Journal of Australia. 02: 02. 2021. PMID: 34856023. 10.1002/hpja.562. KQ1E3a, KQ2E3a, KQ3E3a34856023
44 Ekici, N, Suzer Ozkan, F. Effect of White Noise on Anxiety Levels and Breastfeeding Success of Primiparous Mothers Having Vaginal Delivery: A Randomized Controlled Trial. Breastfeeding Medicine: The Official Journal of the Academy of Breastfeeding Medicine. 02: 02. 2024. PMID: 38563424. 10.1089/bfm.2023.0309. KQ1E5, KQ2E5, KQ3E538563424
45 Eksioglu, A, Yesil, Y, . The Effects of Different Breastfeeding Training Techniques Given for Primiparous Mothers Before Discharge on the Incidence of Cracked Nipples. Breastfeeding Medicine: The Official Journal of the Academy of Breastfeeding Medicine. 12: 311–315. 2017. PMID: 28472588. 10.1089/bfm.2016.0150. KQ1E3a, KQ2E3a, KQ3E3a28472588
46 Estafanous, M, Lee, A, . Breastfeeding and Antepartum Breast Milk Expression (BABE): A Randomized Control Trial Utilizing an Electric Breast Pump and its Effect on Postpartum Breastfeeding. Breastfeeding Medicine: The Official Journal of the Academy of Breastfeeding Medicine. 18(10): 759–766. 2023. PMID: 37782909. 10.1089/bfm.2023.0053. KQ1E6a, KQ2E6a, KQ3E6a37782909
47 Fangupo, LJ, Heath, AL, . Impact of an early-life intervention on the nutrition behaviors of 2-y-old children: a randomized controlled trial. Am J Clin Nutr. 102(3): 704–12. 2015. PMID: 26224299. 10.3945/ajcn.115.111823. KQ1E5, KQ2E5, KQ3E526224299
48 Fewtrell, Mary, Kennedy, Kathy, . Short-term efficacy of two breast pumps and impact on breastfeeding outcomes at 6 months in exclusively breastfeeding mothers: A randomised trial. Matern Child Nutr. 15(3): N.PAG-N.PAG. 2019. 10.1111/mcn.12779. KQ1E1, KQ2E1, KQ3E1
49 Forster, D, McLardie-Hore, F, . Ringing up about breastfeeding: a random controlled trial exploring early telephone peer support for breastfeeding (RUBY) – primary outcomes. Women and birth. 30(S1): 8. 2018. PMID: 24886264. 10.1186/1471-2393-14-177. KQ1E8, KQ2E8, KQ3E824886264
50 Gabbe, Patricia, Reno, Rebecca, . Improving Maternal and Infant Child Health Outcomes with Community-Based Pregnancy Support Groups: Outcomes from Moms2B Ohio. Matern Child Health J. 21(5): 1130–1138. 2017. 10.1007/s10995-016-2211-x. KQ1E3a, KQ2E3a, KQ3E3a28074311
51 Galland, BC, Sayers, RM, . Anticipatory guidance to prevent infant sleep problems within a randomised controlled trial: infant, maternal and partner outcomes at 6 months of age. BMJ Open. 7(5): e014908. 2017. PMID: 28576897. 10.1136/bmjopen-2016-014908. KQ1E1, KQ2E1, KQ3E128576897
52 Giugliani, ERJ, Nunes, LM, . Involvement of maternal grandmother and teenage mother in intervention to reduce pacifier use: a randomized clinical trial. J Pediatr (Rio J). 95(2): 166–172. 2019. PMID: 29447832. 10.1016/j.jped.2017.12.011. KQ1E2a, KQ2E2a, KQ3E2a29447832
53 Gonzalez-Darias, A, Diaz-Gomez, NM, . ‘Supporting a first-time mother’: Assessment of success of a breastfeeding promotion programme. Midwifery. 85: 102687. 2020. 10.1016/j.midw.2020.102687. KQ1E5, KQ2E7, KQ3E732163797
54 Gouchon, S, Gregori, D, . Skin-to-skin contact after cesarean delivery: an experimental study. Nurs Res. 59(2): 78–84. 2010. PMID: 20179657. 10.1097/NNR.0b013e3181d1a8bc. KQ1E6c, KQ2E6c, KQ3E6c20179657
55 Gregson, Sarah, Meadows, Jean, . Skin-to-skin contact after elective caesarean section: Investigating the effect on breastfeeding rates. British Journal of Midwifery. 24(1): 18–25. 2016. 10.12968/bjom.2016.24.1.18. KQ1E6c, KQ2E6c, KQ3E6c
56 Griffin, L, Lopez, J, . Does increased use of breastfeeding smartphone applications improve breastfeeding rates among low-income women?. Breastfeeding medicine. 15(10): A28–a29. 2020. PMID: CN-02229740. 10.1089/bfm.2020.29162.abstracts. KQ1E8, KQ2E8, KQ3E8
57 Grimes, Heather, Forster, Della, . Volunteers’ experiences of providing breastfeeding peer support in the ‘Ringing Up about Breastfeeding’ (RUBY) randomised controlled trial. Women & Birth. 31: S33–S34. 2018. PMID: 132719275. 10.1016/j.wombi.2018.08.103. KQ1E8, KQ2E8, KQ3E8
58 Hails, KA, Whipps, MDM, . Breastfeeding and Responsive Parenting as Predictors of Infant Weight Change in the First Year. J Pediatr Psychol. 46(7): 768–778. 2021. PMID: 34270767. 10.1093/jpepsy/jsab049. KQ1E1, KQ2E1, KQ3E134270767
59 Harris-Luna, ML, Badr, LK. Pragmatic Trial to Evaluate the Effect of a Promotora Telephone Intervention on the Duration of Breastfeeding. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. 47(6): 738–748. 2018. 10.1016/j.jogn.2018.09.001. KQ1E3a, KQ2E3a, KQ3E3a
60 Havens, Jessica Mary Evelyn, Wines, Maria. Screening for Mothers at Risk to Wean Early and Referral to a Lactation Support Person for Prolonging Breastfeeding. Journal of Perinatal Education. 28(1): 51–60. 2019. PMID: 134987983. 10.1891/1058-1243.28.1.51. KQ1E5, KQ2E7, KQ3E531086475
61 Hawkins, SS, Stern, AD, . Compliance with the Baby-Friendly Hospital Initiative and impact on breastfeeding rates. Arch Dis Child Fetal Neonatal Ed. 99(2): F138–43. 2014b. PMID: 24277661. 10.1136/archdischild-2013-304842. KQ1E6b, KQ2E6b, KQ3E6b24277661
62 Hawkins, SS, Stern, AD, . Evaluating the impact of the Baby-Friendly Hospital Initiative on breast-feeding rates: a multi-state analysis. Public Health Nutr. 1–9. 2014a. PMID: 24625787. 10.1017/s1368980014000238. KQ1E6b, KQ2E6b, KQ3E6b24650538
63 Hermanson, A, Astrand, LL. The effects of early pacifier use on breastfeeding: A randomised controlled trial. Women & Birth: Journal of the Australian College of Midwives. 33(5): e473–e482. 2020. PMID: 31704126. 10.1016/j.wombi.2019.10.001. KQ1E6d, KQ2E6d, KQ3E6d31704126
64 HM Wasser, AL Thompson, CM Suchindran, BD Goldman, . Home-based intervention for non-Hispanic black families finds no significant difference in infant size or growth: results from the Mothers & Others randomized controlled trial. BMC Pediatr. 20(1). 2020. PMID: 32811460. 10.1186/s12887-020-02273-9. KQ1E5, KQ2E5, KQ3E532811460
65 Hoddinott, P, Britten, J, . Effectiveness of policy to provide breastfeeding groups (BIG) for pregnant and breastfeeding mothers in primary care: cluster randomised controlled trial. BMJ. 338: a3026. 2009. PMID: 19181729. 10.1136/bmj.a3026. KQ1E6b, KQ2E6b, KQ3E6b19181729
66 Horodynski, MA, Pierce, SJ, . Feeding Practices and Infant Growth: Quantifying the Effects of Breastfeeding Termination and Complementary Food Introduction on BMI z-Score Growth Velocity through Growth Curve Models. Childhood Obesity. 13(6): 490–498. 2017. PMID: 28767287. 10.1089/chi.2017.0079. KQ1E3a, KQ2E3a, KQ3E3a28767287
67 Hosseini, Sa, Vakilian, K, . Effect of Midwife-led Breastfeeding Counseling based on Bandura’s Model on Self-efficacy and Breastfeeding Performance: an Educational Trial Study. Open public health journal. 16(1). 2023. 10.2174/18749445-v16-230221-2022-174. Howard, CR, Howard, FM, . KQ1E2a, KQ2E2a, KQ3E2a
68 Randomized clinical trial of pacifier use and bottle-feeding or cupfeeding and their effect on breastfeeding. Pediatrics. 111(3): 511–518. 2003. PMID: 12612229. 10.1542/peds.111.3.511. KQ1E6d, KQ2E6d, KQ3E6d12612229
69 Hoyt-Austin, AE, Cheng, JH, . Providing Low-Income Women With a Manual Pump: A Pilot Study. Hospital Pediatrics. 13(2): 115–124. 2023. PMID: 36646639. 10.1542/hpeds.2021-006380. KQ1E5, KQ2E7, KQ3E536646639
70 Huang, P, Yao, J, . Individualized intervention to improve rates of exclusive breastfeeding: A randomised controlled trial. Medicine (Baltimore). 98(47): e17822. 2019. PMID: 31764775. 10.1097/MD.0000000000017822. KQ1E2a, KQ2E2a, KQ3E2a31764775
71 Huang, X, Chen, L, . Effects of Paternal Skin-to-Skin Contact in Newborns and Fathers After Cesarean Delivery. Journal of Perinatal & Neonatal Nursing. 33(1): 68–73. 2019. PMID: 30676465. 10.1097/JPN.0000000000000384. KQ1E2a, KQ2E2a, KQ3E2a30676465
72 J Banna, M Campos, C Gibby, RE Graulau, . Multi-site trial using short mobile messages (SMS) to improve infant weight in low-income minorities: Development, implementation, lessons learned and future applications. Contemp Clin Trials. 62. 2017. PMID: 2887160. 10.1016/j.cct.2017.08.011. KQ1E7a, KQ2E7a, KQ3E7a2887160
73 Jenik, AG, Vain, NE, . Does the recommendation to use a pacifier influence the prevalence of breastfeeding?. J Pediatr. 155(3): 350–4. 2009. PMID: 19464025. 10.1016/j.jpeds.2009.03.038. KQ1E6d, KQ2E6d, KQ3E6d19464025
74 Kao, JC, Johnson, JE, . The Positive Effect of a Group Intervention to Reduce Postpartum Depression on Breastfeeding Outcomes in Low-Income Women. Int J Group Psychother. 65(3): 445–58. 2015. PMID: 26076207. 10.1521/ijgp.2015.65.3.445. KQ1E1, KQ2E1, KQ3E126076207
75 Kapinos, K, Kotzias, V, . The Use of and Experiences With Telelactation Among Rural Breastfeeding Mothers: Secondary Analysis of a Randomized Controlled Trial. J Med Internet Res. 21(9): e13967. 2019. PMID: 31482848. 10.2196/13967. KQ1E5, KQ2E5, KQ3E531482848
76 Kellams, A, Kerr, SM, . The Impact of Breastfeeding and Safe Sleep Mobile Health Messaging on Breastfeeding and Bedsharing. Acad Pediatr. 04: 04. 2022. PMID: 35124281. 10.1016/j.acap.2022.01.016. KQ1E1, KQ2E1, KQ3E135124281
77 Kim, Tae-Hee, Lee, Hae-Hyeog, . Re: Professional breastfeeding support for first-time mothers: a multi-centre cluster randomised controlled trial. PMID: 27753249 10.1111/1471-0528.14121. KQ1E8, KQ2E8, KQ3E827753249
78 Kim, TH, Lee, HH, . Re: Professional breastfeeding support for first-time mothers: a multi-centre cluster randomised controlled trial. BJOG: An International Journal of Obstetrics & Gynaecology. 123(12): 2052. 2016. PMID: 27753249. 10.1111/1471-0528.14121. KQ1E8, KQ2E8, KQ3E827753249
79 Kluka, SM. A randomized controlled trial to test the effect of an antenatal educational intervention on breastfeeding duration among primiparous women. (Ph.D.): 219 p–219 p. 2004. KQ1E5, KQ2E8, KQ3E5
80 Korgali, E, Orhon, F. The Effects of Education Program Applied to the Families of Moderate and Late Premature Infants on Breastfeeding, Parental-infant Attachment and Parents’ Anxiety Levels in the First Year: a Randomised Controlled Trial. Hong kong journal of paediatrics. 28(3): 144–156. 2023. KQ1E4a, KQ2E4a, KQ3E4a
81 Kramer, MS, Barr, RG, . Pacifier use, early weaning, and cry/fuss behavior: a randomized controlled trial. JAMA. 286(3): 322–326. 2001. PMID: 11466098. 10.1001/jama.286.3.322. KQ1E6d, KQ2E6d, KQ3E6d11466098
82 Krowchuk, HeidiV. TOWARD EVIDENCE-BASED PRACTICE. Online Participatory Intervention to Promote and Support Exclusive Breastfeeding: Randomized Clinical Trial. MCN: The American Journal of Maternal Child Nursing. 44(6): 366–366. 2019. 10.1097/NMC.0000000000000577. KQ1E2a, KQ2E2a, KQ3E2a
83 Kul Uctu, A, Ozerdogan, N. Effect of teach-back method on breastfeeding success: A single blind randomized controlled study. Health Care Women Int. 1–14. 2022. PMID: 35175908. 10.1080/07399332.2021.2021915. KQ1E5, KQ2E5, KQ3E535175908
84 Kul Uctu, Arzu, Ozerdogan, Nebahat. Effect of teach-back method on breastfeeding success: A single blind randomized controlled study. Health Care Women Int. 44(3): 314–327. 2023. 10.1080/07399332.2021.2021915. KQ1E5, KQ2E5, KQ3E535175908
85 Lambermon, FJ, van Duijnhoven, NTL, . Client-centered flexible planning of home-based postpartum care: A randomized controlled trial on the quality of care. Birth. 08: 08. 2024. PMID: 38716628. 10.1111/birt.12824. KQ1E3b, KQ2E3b, KQ3E3b38716628
86 Lee, Yi-Hua, Chang, Guey-Ling, . Effects of education and support groups organized by IBCLCs in early postpartum on breastfeeding. Midwifery. 75: 5–11. 2019. 10.1016/j.midw.2019.03.023. KQ1E3a, KQ2E3a, KQ3E3a30974334
87 Lewkowitz, AdamK, Lopez, JuliaD, . 45: Impact of a novel smartphone application on low-income women’s breastfeeding rates: a randomized controlled trial. Am J Obstet Gynecol. 222(1): S38–S39. 2020. PMID: 140989549. 10.1016/j.ajog.2019.11.061. KQ1E8, KQ2E8, KQ3E8
88 Li, G, Cong, J, . Effects of nursing with information support and behavior intervention on lactation and breastfeeding success rate for primiparas. Int J Clin Exp Med. 11(3): 2617–2623. 2018. KQ1E2a, KQ2E2a, KQ3E2a
89 Liao, Q, Chen, L, . Effect of kangaroo mother care method on pain, growth and breastfeeding in newborns. Int J Clin Exp Med. 13(6): 4403–4408. 2020. KQ1E2a, KQ2E2a, KQ3E2a
90 Liu, Lingying, Zhu, Jiemin, . The effect of a perinatal breastfeeding support program on breastfeeding outcomes in primiparous mothers. West J Nurs Res. 39(7): 906–923. 2017. 10.1177/0193945916670645. KQ1E2a, KQ2E2a, KQ3E2a27681668
91 Lok, KY, Chow, CLY, . Feasibility, acceptability, and potential efficacy of an innovative postnatal home-based breastfeeding peer support programme in Hong Kong: a feasibility and pilot randomised controlled trial. Int Breastfeed J. 16(1): 34. 2021. PMID: 33849582. 10.1186/s13006-021-00381-5. KQ1E5, KQ2E7, KQ3E533849582
92 Lucchini-Raies, C, Marquez-Doren, F, . The CRIAA Program complex intervention in primary care to support women and their families in breastfeeding: Study protocol for a pilot trial. J Adv Nurs. 76(12): 3641–3653. 2020. PMID: 33058232. 10.1111/jan.14534. KQ1E5, KQ2E5, KQ3E533058232
93 Lucchini-Raies, Camila, Marque-zDoren, Francisca, . A complex intervention to support breastfeeding: A feasibility and acceptability study. International Journal of Nursing Practice (John Wiley & Sons, Inc.). 29(6): 1–15. 2023. 10.1111/ijn.13184. KQ1E3a, KQ2E3a, KQ3E3a
94 Mackert, Michael, Guadagno, Marie, . Improving gestational weight gain and breastfeeding promotion: Visual communication to overcome health literacy barriers. J Commun Healthc. 9(2): 90–97. 2016. 10.1080/17538068.2016.1168199. KQ1E3a, KQ2E3a, KQ3E3a
95 Marshall, S, Xu, H, . Engagement, satisfaction, retention and behavioural outcomes of linguistically diverse mothers and infants participating in an Australian early obesity prevention trial. Health Promotion Journal of Australia. 10: 10. 2021. PMID: 34245623. 10.1002/hpja.521. KQ1E5, KQ2E5, KQ3E534245623
96 Marshall, Sarah, Taki, Sarah, . Feasibility of a culturally adapted early childhood obesity prevention program among migrant mothers in Australia: a mixed methods evaluation. BMC Public Health. 21(1): 1–18. 2021. 10.1186/s12889-021-11226-5. KQ1E5, KQ2E5, KQ3E533388037
97 Martin, J, MacDonald-Wicks, L, . Reducing postpartum weight retention and improving breastfeeding outcomes in overweight women: a pilot randomised controlled trial. Nutrients. 7(3): 1464–79. 2015. PMID: 25723973. 10.3390/nu7031464. KQ1E5, KQ2E5, KQ3E525723973
98 Martinez, JosefaL. Predictors of exclusive breastfeeding behavior in low-income women attending the special supplemental nutrition program for women, infants, and children. Dissertation Abstracts International: Section B: The Sciences and Engineering. 78(7-B(E)): No Pagination Specified. 2018. KQ1E5, KQ2E5, KQ3E5
99 Martinez-Brockman, JL, Harari, N, . A qualitative analysis of text message conversations in a breastfeeding peer counselling intervention. Matern Child Nutr. 16(2): e12904. 2020. PMID: 31823503. 10.1111/mcn.12904. KQ1E7a, KQ2E7a, KQ3E7a31823503
100 Martinez-Brockman, JL, Harari, N, . Impact of the Lactation Advice Through Texting Can Help (LATCH) Trial on Time to First Contact and Exclusive Breastfeeding among WIC Participants. J Nutr Educ Behav. 50(1): 33–42.e1. 2018. PMID: 29325660. 10.1016/j.jneb.2017.09.001. KQ1E5, KQ2E7, KQ3E529325660
101 Maycock, BR, Scott, JA, . A study to prolong breastfeeding duration: design and rationale of the Parent Infant Feeding Initiative (PIFI) randomised controlled trial. BMC Pregnancy Childbirth. 15: 159. 2015. PMID: 26231519. 10.1186/s12884-015-0601-5. KQ1E7a, KQ2E7a, KQ3E7a26231519
102 McGinnis, Sandra, Lee, Eunju, . Let’s Talk About Breastfeeding: The Importance of Delivering a Message in a Home Visiting Program. American Journal of Health Promotion. 32(4): 989–996. 2018. 10.1177/0890117117723802. KQ1E3a, KQ2E3a, KQ3E3a28830205
103 Mersky, JP, Janczewski, CE, . Home Visiting Effects on Breastfeeding and Bedsharing in a Low-Income Sample. Health Education & Behavior. 48(4): 488–495. 2021. PMID: 33078655. 10.1177/1090198120964197. KQ1E3a, KQ2E3a, KQ3E3a33078655
104 Mizrak, Berrak, Ozerdogan, Nebahat, . The Effect of Antenatal Education on Breastfeeding Self-Efficacy: Primiparous Women in Turkey. International Journal of Caring Sciences. 10(1): 503–510. 2017. PMID: 123010481. K1E5, KQ2E5, KQ3E5
105 Molinero, Diaz P, Burgos, Rodriguez Mj, . Results of a health education intervention in the continuity of breastfeeding. Enferm Clin. 25(5): 232–238. 2015. 10.1016/j.enfcli.2015.05.002. KQ1E8, KQ2E8, KQ3E826232144
106 Montazeri, Maryam, Mirghafourvand, Mojgan, . Effects of journal therapy counseling with anxious pregnant women on their infants’ sleep quality: a randomized controlled clinical trial. BMC Pediatr. 20(1): 1–11. 2020. PMID: 143297094. 10.1186/s12887-020-02132-7. KQ1E2a, KQ2E2a, KQ3E2a31900152
107 Moon, RY, Mathews, A, . Impact of a Randomized Controlled Trial to Reduce Bedsharing on Breastfeeding Rates and Duration for African-American Infants. J Community Health. 42(4): 707–715. 2017. PMID: 28064421. 10.1007/s10900-016-0307-2. KQ1E6a, KQ2E6a, KQ3E6a28064421
108 Moorhead, AM, Amir, LH, . Breastfeeding outcomes at 3 months for women with diabetes in pregnancy: Findings from the Diabetes and Antenatal Milk Expressing randomized controlled trial. Birth. 09: 09. 2024. PMID: 38193243. 10.1111/birt.12807. KQ1E6a, KQ2E6a, KQ3E6a38193243
109 Mosca, F, Roggero, P, . Determinants of breastfeeding discontinuation in an Italian cohort of mother-infant dyads in the first six months of life: a randomized controlled trial. Ital J Pediatr. 44(1): 134. 2018. PMID: 30400806. 10.1186/s13052-018-0572-z. KQ1E6a, KQ2E6a, KQ3E6a30400806
110 Mulupuru, Suseela, Siddu, Anita, . Breast crawl at birth, effect on breastfeeding rate and infant growth in infants delivered at an urban tertiary care public hospital: A randomized controlled trial. Journal of Neonatal Nursing. 25(5): 236–239. 2019. PMID: 138458507. 10.1016/j.jnn.2019.04.008. KQ1E2a, KQ2E2a, KQ3E2a
111 Necipoglu, D, Bebis, H, . The effect of nursing interventions on immigrant women living in Northern Cyprus on their breastfeeding self-efficacy and success: a randomized controlled trial. Health Care Women Int. 42(2): 235–247. 2021. PMID: 33667155. 10.1080/07399332.2021.1883023. KQ1E5, KQ2E5, KQ3E533667155
112 Nolan, A, Lawrence, C. A pilot study of a nursing intervention protocol to minimize maternal-infant separation after Cesarean birth. J Obstet Gynecol Neonatal Nurs. 38(4): 430–42. 2009. PMID: 19614878. 10.1111/j.1552-6909.2009.01039.x. KQ1E6c, KQ2E6c, KQ3E6c19614878
113 Oksuz, SK, Inal, S. The effect of kangaroo mother care applied to the healthy newborns in the early postpartum period on breastfeeding: A randomized controlled trial. JPMA - Journal of the Pakistan Medical Association. 71(9): 2124–2129. 2021. PMID: 34580499. 10.47391/JPMA.376. KQ1E5, KQ2E5, KQ3E534580499
114 Padua, Ana Rita, Melo, Elsa Maria, . An intervention program based on regular home visits for improving maternal breastfeeding self-efficacy: A pilot study in portugal. Matern Child Health J. No Pagination Specified. 2022. 10.1007/s10995-021-03361-7. KQ1E3a, KQ2E3a, KQ3E3a
115 Palacios, C, Campos, M, . Effect of a Multi-Site Trial using Short Message Service (SMS) on Infant Feeding Practices and Weight Gain in Low-Income Minorities. J Am Coll Nutr. 37(7): 605–613. 2018. PMID: 29708471. 10.1080/07315724.2018.1454353. KQ1E7, KQ2E7, KQ3E529708471
116 Panahi, F, Rashidi Fakari, F, . Educating fathers to improve exclusive breastfeeding practices: a randomized controlled trial. BMC Health Serv Res. 22(1): 554. 2022. PMID: 35468827. 10.1186/s12913-022-07966-8. KQ1E2a, KQ2E2a, KQ3E2a35468827
117 Park, Mk, Moon, Sh. Effects of an Individual Breast-feeding Promotion Program for Married Immigrant Women. J Korean Acad Nurs. 46(1): 128–139. 2016. 10.4040/jkan.2016.46.1.128. KQ1E8, KQ2E8, KQ3E826963422
118 Pouraboli, Batool, Estabraghi, Mahdieh, . THE EFFECT OF EARLY SKIN TO SKIN CONTACT IN TERM NEONATES AFTER C-SECTION ON BREASTFEEDING CHOICE AT THE TIME OF DISCHARGE. Journal on Nursing. 9(2): 1–8. 2019. 10.26634/jnur.9.2.15981. KQ1E2a, KQ2E2a, KQ3E2a
119 Raat, H, Struiji, MK, . Primary prevention of overweight in preschool children, the BeeBOFT study (breastfeeding, breakfast daily, outside playing, few sweet drinks, less TV viewing): design of a cluster randomized controlled trial. BMC Public Health. 13(974). 2013. PMID: 24138805. 10.1186/1471-2458-13-974. KQ1E7a, KQ2E7a, KQ3E7a24138805
120 Raj Kumawat, S, Vyas, H, . 90 versus 60 min of early skin-to-skin contact on exclusive breastfeeding rate in healthy infants’ >=35 weeks: A randomised controlled trial. Acta Paediatr. 113(2): 199–205. 2024. PMID: 37905336. 10.1111/apa.17021. KQ1E3b, KQ2E3b, KQ3E3b37905336
121 Reifsnider, E, McCormick, DP, . Randomized Controlled Trial to Prevent Infant Overweight in a High-Risk Population. Acad Pediatr. 18(3): 324–333. 2018. PMID: 29277462. 10.1016/j.acap.2017.12.007. KQ1E7, KQ2E7, KQ3E529277462
122 Relton, C, Strong, M, . Effect of Financial Incentives on Breastfeeding: A Cluster Randomized Clinical Trial. JAMA Pediatr. 172(2): e174523. 2018. PMID: 29228160. 10.1001/jamapediatrics.2017.4523. KQ1E6a, KQ2E6a, KQ3E6a29228160
123 Robling, M, Bekkers, MJ, . Effectiveness of a nurse-led intensive home-visitation programme for first-time teenage mothers (Building Blocks): a pragmatic randomised controlled trial. Lancet. 387(10014): 146–55. 2016. PMID: 26474809. 10.1016/S0140-6736(15)00392-X. KQ1E1, KQ2E1, KQ3E126474809
124 Rodriguez-Gallego, I, Corrales-Gutierrez, I, . Effectiveness of a Postpartum Breastfeeding Support Group Intervention in Promoting Exclusive Breastfeeding and Perceived Self-Efficacy: A Multicentre Randomized Clinical Trial. Nutrients. 16(7): 28. 2024. PMID: 38613021. 10.3390/nu16070988. KQ1E7, KQ2E7, KQ3E538613021
125 Rodriguez-Gallego, I, Leon-Larios, F, . Evaluation of the impact of breastfeeding support groups in primary health CENTRES in Andalusia, Spain: a study protocol for a cluster randomized controlled trial (GALMA project). BMC Public Health. 20(1): 1129. 2020. PMID: 32682408. 10.1186/s12889-020-09244-w. KQ1E5, KQ2E7a, KQ3E532682408
126 Rodriguez-Gallego, I, Vila-Candel, R, . Evaluation of the Impact of a Midwife-Led Breastfeeding Group Intervention on Prevention of Postpartum Depression: A Multicentre Randomised Clinical Trial. Nutrients. 16(2): 10. 2024. PMID: 38257120. 10.3390/nu16020227. KQ1E5, KQ2E7a, KQ3E538257120
127 Rosas, Bs, Rodriguez, J, . Effect of skin to skin care on the success of breastfeeding exlusivity: a randomised controlled trial. Pediatric academic societies (PAS) annual meeting; 2015 apr 25 - 28; San Diego, USA. 2015. KQ1E8, KQ2E8, KQ3E8
128 Rosas-Herrera, Bs, Rodríguez-de, Ita J, . Impact of skin-to-skin contact at birth on exclusive breastfeeding and the regulation of vital signs. Salud Publica Mex. 61(5): 560. 2019. PMID: 31661733. 10.21149/10477. KQ1E8, KQ2E8, KQ3E831661733
129 Rotheram-Fuller, EJ, Swendeman, D, . Replicating Evidence-Based Practices with Flexibility for Perinatal Home Visiting by Paraprofessionals. Matern Child Health J. 21(12): 2209–2218. 2017. PMID: 28755042. 10.1007/s10995-017-2342-8. KQ1E7, KQ2E7, KQ3E728755042
130 Rouse, CandaceL. Increasing Initiation and Exclusivity of Breastfeeding In the Hospitalized Postpartum Dyad. (D.N.P.): 69 p–69 p. 2015. KQ1E8, KQ2E8, KQ3E8
131 Saunders, CM, Rehbinder, EM, . Feeding Practices and Dietary Diversity in the First Year of Life: PreventADALL, a Scandinavian Randomized Controlled Trial and Birth Cohort Study. J Nutr. 153(8): 2463–2471. 2023. PMID: 37336319. 10.1016/j.tjnut.2023.06.015. KQ1E1, KQ2E1, KQ3E137336319
132 Savas, EH, Semerci, R, . Impact of psychosexual development theory-based breastfeeding education on infant feeding attitudes and knowledge of primiparous mothers: A randomized controlled study. J Pediatr Nurs. 17: 17. 2024. PMID: 38762425. 10.1016/j.pedn.2024.05.016. KQ1E5, KQ2E5, KQ3E538762425
133 Schiller, T, Gassner, T, . Prenatal Breastfeeding Counseling Intervention in Women with Pre-Gestational Diabetes Mellitus-A Randomized Controlled Trial. Healthcare. 12(3): 04. 2024. PMID: 38338291. 10.3390/healthcare12030406. KQ1E3a, KQ2E3a, KQ3E3a38338291
134 Schwartz, R, Vigo, A, . The effect of a pro-breastfeeding and healthy complementary feeding intervention targeting adolescent mothers and grandmothers on growth and prevalence of overweight of preschool children. PLoS One. 10(7). 2015. 10.1371/journal.pone.0131884. KQ1E2a, KQ2E2a, KQ3E2a
135 Scott, JA, Burns, SK, . Impact of a Face-To-Face Versus Smartphone App Versus Combined Breastfeeding Intervention Targeting Fathers: Randomized Controlled Trial. JMIR Pediatrics and Parenting. 4(2): e24579. 2021. PMID: 33843604. 10.2196/24579. KQ1E7, KQ2E7, KQ3E733843604
136 Sharma, A. Efficacy of early skin-to-skin contact on the rate of exclusive breastfeeding in term neonates: a randomized controlled trial. Afr Health Sci. 16(3): 790–797. 2016. PMID: 27917213. 10.4314/ahs.v16i3.20. KQ1E2a, KQ2E2a, KQ3E2a27917213
137 Shaughnessy, AF. Provided Infant Carriers Increase the Rate of Sustained Breastfeeding. Am Fam Physician. 105(1): 93–94. 2022. PMID: 35029950. KQ1E8, KQ2E8, KQ3E835029950
138 Shipp, GM, Weatherspoon, LJ, . Breastfeeding Self-Efficacy as a Predictor of Breastfeeding Intensity Among African American Women in the Mama Bear Feasibility Trial. Breastfeeding Medicine: The Official Journal of the Academy of Breastfeeding Medicine. 15: 15. 2022. PMID: 35166571. 10.1089/bfm.2021.0301. KQ1E5, KQ2E5, KQ3E535166571
139 Shipp, GM, Weatherspoon, LJ, . Understanding the Impact of Perceived Social Support for Breastfeeding Among African American Women: Results From the Mama Bear Feasibility Trial. Am J Health Promot. 2022. PMID: 36330772. 10.1177/08901171221138275. KQ1E5, KQ2E5, KQ3E536330772
140 Şimşek, Songül, Karahan, Nazan. Assessment of The Impact of Mother-Infant Skin-to-Skin Contact at Childbirth on Breastfeeding. Konuralp Medical Journal / Konuralp Tip Dergisi. 9(1): 70–77. 2017. 10.18521/ktd.296559. KQ1E5, KQ2E5, KQ3E5
141 Souza, Efdc, Pina-Oliveira, AA, . Effect of a breastfeeding educational intervention: a randomized controlled trial. Rev Lat Am Enfermagem. 28: e3335. 2020. PMID: 33027400. 10.1590/1518-8345.3081.3335. KQ1E2a, KQ2E2a, KQ3E2a33027400
142 Sreekumar, Kavita, D’Lima, Annely, . Cognitive Breastfeeding Counseling: A Single Session Helps Improve LATCH Score. Journal of Perinatal Education. 27(3): 148–151. 2018. 10.1891/1058-1243.27.3.148. KQ1E2a, KQ2E2a, KQ3E2a30364260
143 Stuebe, AM, Bonuck, K, . A Cluster Randomized Trial of Tailored Breastfeeding Support for Women with Gestational Diabetes. Breastfeeding Medicine: The Official Journal of the Academy of Breastfeeding Medicine. 11: 504–513. 2016. PMID: 27782758. 10.1089/bfm.2016.0069. KQ1E7, KQ2E7, KQ3E527782758
144 Taheri, Z, Bakouei, F, . Effectiveness of distance education program on mothers’ empowerment in exclusive breastfeeding: A randomized clinical trial. J Educ Health Promot. 11: 420. 2022. PMID: 36824088. 10.4103/jehp.jehp_1614_21. KQ1E2a, KQ2E2a, KQ3E2a36824088
145 Tarrant, Marie. Author’s reply re: Professional breastfeeding support for first-time mothers: a multi-centre cluster randomised controlled trial. Kim TH, Lee HH, Kim JM, . Professional breastfeeding support for first-time mothers: a multi-centre cluster randomised controlled trial. BJOG, 2016;123(12):2052–2052. . 123: 2052–2053. 2016. PMID: 27753257. 10.1111/1471-0528.14122. KQ1E8, KQ2E8, KQ3E827753257
146 Taylor, RW, Williams, SM, . Effect of a Baby-Led Approach to Complementary Feeding on Infant Growth and Overweight: A Randomized Clinical Trial. JAMA Pediatr. 171(9): 838–846. 2017. PMID: 28692728. 10.1001/jamapediatrics.2017.1284. KQ1E1, KQ2E1, KQ3E128692728
147 Tender, JenniferAF, Henderson, Chrisonne, . Integrating a Breastfeeding Peer Counselor Into an Academic Hospital’s Obstetric Clinic: A Pilot Study. Journal of Perinatal Education. 33(2): 81–87. 2024. 10.1891/JPE-2023-0003. KQ1E5, KQ2E7, KQ3E539399785
148 Tseng, JF, Chen, SR, . Effectiveness of an integrated breastfeeding education program to improve self-efficacy and exclusive breastfeeding rate: A single-blind, randomised controlled study. Int J Nurs Stud. 111: 103770. 2020. PMID: 32961461. 10.1016/j.ijnurstu.2020.103770. KQ1E2a, KQ2E2a, KQ3E2a32961461
149 Tubay, AT, Mansalis, KA, . The Effects of Group Prenatal Care on Infant Birthweight and Maternal Well-Being: A Randomized Controlled Trial. Mil Med. 184(5–6): e440–e446. 2019. PMID: 30535396. 10.1093/milmed/usy361. KQ1E7, KQ2E7, KQ3E730535396
150 Ulloa Sabogal, IM, Dominguez Narino, CC, . Educational intervention for the maintenance of exclusive breastfeeding in adolescent mothers: A feasibility study. Int J Nurs Knowl. 21: 21. 2022. PMID: 36269054. 10.1111/2047-3095.12404. KQ1E2a, KQ2E2a, KQ3E2a36269054
151 Vila-Candel, R, Mena-Tudela, D, . Effects of a mobile application on breastfeeding maintenance in the first 6 months after birth: Randomised controlled trial (COMLACT study). Midwifery. 128: 103874. 2024. PMID: 37979550. 10.1016/j.midw.2023.103874. KQ1E5, KQ2E7, KQ3E537979550
152 Vlasblom, E, van Grieken, A, . Parenting support to prevent overweight during regular well-child visits in 0-3 year old children (BBOFT+ program), a cluster randomized trial on the effectiveness on child BMI and health behaviors and parenting. PLoS ONE [Electronic Resource]. 15(8): e0237564. 2020. PMID: 32810194. 10.1371/journal.pone.0237564. KQ1E5, KQ2E7, KQ3E532810194
153 Wagijo, MA, Crone, M, . The Effect of CenteringPregnancy Group Antenatal Care on Maternal, Birth, and Neonatal Outcomes Among Low-Risk Women in the Netherlands: A Stepped-Wedge Cluster Randomized Trial. J Midwifery Womens Health. 69(2): 191–201. 2024. PMID: 38339816. 10.1111/jmwh.13582. KQ1E3a, KQ2E3a, KQ3E3a38339816
154 Washio, Y, Humphreys, M, . Incentive-based Intervention to Maintain Breastfeeding Among Low-income Puerto Rican Mothers. Pediatrics. 139(3). 2017. PMID: 28167511. 10.1542/peds.2016-3119. KQ1E6a, KQ2E6a, KQ3E6a28167511
155 Wen, J, Yu, G, . Effects of a theory of planned behavior-based intervention on breastfeeding behaviors after cesarean section: A randomized controlled trial. International Journal of Nursing Sciences. 8(2): 152–160. 2021. PMID: 33997128. 10.1016/j.ijnss.2021.03.012. KQ1E2a, KQ2E2a, KQ3E2a33997128
156 White, B, Giglia, RC, . Gamifying Breastfeeding for Fathers: Process Evaluation of the Milk Man Mobile App. JMIR Pediatrics and Parenting. 2(1): e12157. 2019. PMID: 31518324. 10.2196/12157. KQ1E7a, KQ2E7a, KQ3E7a31518324
157 White, BK, Burns, SK, . Designing evaluation plans for health promotion mHealth interventions: a case study of the Milk Man mobile app. Health Promotion Journal of Australia. 27(3): 198–203. 2016. PMID: 27784506. 10.1071/HE16041. KQ1E7a, KQ2E7a, KQ3E7a27784506
158 Wilkinson, SA, van der Pligt, P, . Trial for Reducing Weight Retention in New Mums: a randomised controlled trial evaluating a low intensity, postpartum weight management programme. J Hum Nutr Diet. 28 Suppl 1: 15–28. 2015. PMID: 24267102. 10.1111/jhn.12193. KQ1E1, KQ2E1, KQ3E124267102
159 Wong, MS, Chien, WT. A Pilot Randomized Controlled Trial of an Online Educational Program for Primiparous Women to Improve Breastfeeding. J Hum Lact. 39(1): 107–118. 2023. PMID: 36189735. 10.1177/08903344221125129. KQ1E7, KQ2E7, KQ3E536189735
160 Yesil, Y, Ozturk Can, H. Postpartum Breastfeeding Practices and Attitudes in Parents: A Randomized Study to Evaluate the Effects of Individual and Group Breastfeeding Education of Mothers and Fathers. Cureus. 15(9): e44811. 2023. PMID: 37809220. 10.7759/cureus.44811. KQ1E5, KQ2E7, KQ3E737809220
161 Yildirim Goksen, DF, Ozkan, S. The effect of online breastfeeding education on breastfeeding motivation: A randomized controlled study. J Pediatr Nurs. 75: e42–e48. 2024. PMID: 38182483. 10.1016/j.pedn.2023.12.026. KQ1E5, KQ2E5, KQ3E538182483
162 Yilmaz, M, Aykut, M. The effect of breastfeeding training on exclusive breastfeeding: a randomized controlled trial. Journal of Maternal-Fetal & Neonatal Medicine. 34(6): 925–932. 2021. PMID: 31345049. 10.1080/14767058.2019.1622672. KQ1E5, KQ2E7, KQ3E531345049
163 You, H, Lei, A, . Effects of breastfeeding education based on the self-efficacy theory on women with gestational diabetes mellitus: A CONSORT-compliant randomized controlled trial. Medicine (Baltimore). 99(16): e19643. 2020. PMID: 32311936. 10.1097/MD.0000000000019643. KQ1E2a, KQ2E2a, KQ3E2a32311936
164 Yurtsal, B, Hasdemir, O. Effects of the WhatsApp midwife breastfeeding support line on early postpartum breastfeeding process of mothers. Health Care Women Int. 43(12): 1433–1448. 2022. PMID: 35417317. 10.1080/07399332.2021.1972303. KQ1E5, KQ2E5, KQ3E535417317
165 Zhu, Yu, Zhang, Zhihong, . Impact of intervention on breastfeeding outcomes and determinants based on theory of planned behavior. Women & Birth. 30(2): 146–152. 2017. PMID: 123371331. 10.1016/j.wombi.2016.09.011. KQ1E2a, KQ2E2a, KQ3E2a27773609
166 Zhuang, J. Developing Messages Tailored to Self-construal, Time-orientation, and Perspective Taking to Promote 6-Month Exclusive Breastfeeding. J Health Commun. 26(3): 204–213. 2021. PMID: 33899682. 10.1080/10810730.2021.1903626. KQ1E1, KQ2E1, KQ3E133899682