# Appendix C Included Studies

- Abbass-Dick J, Stern SB, Nelson LE, . Coparenting breastfeeding support and exclusive breastfeeding: a randomized controlled trial. Pediatrics. 2015;135(1):102–10. PMID: 254525653. 10.1542/peds.2014-1416 25452653
  - Abbass-Dick J. Evaluating the effectiveness of a coparenting breastfeeding support intervention (COSI) on exclusive breastfeeding rates at twelve weeks postpartum. PhD, Nursing Science. Lawrence S. Bloomberg Faculty of Nursing. University of Toronto; 2013.
- Abbass-Dick J, Sun W, Newport A, . The comparison of access to an eHealth resource to current practice on mother and co-parent teamwork and breastfeeding rates: A randomized controlled trial. Midwifery. 2020;90:102812. PMID: 32739716. 10.1016/j.midw.2020.102812 32739716
- Acar Z, Sahin N. Development of a mobile application-based breastfeeding program and evaluation of its effectiveness. J Pediatr Nurs. 2024;74:51–60. PMID: 37995477. 10.1016/j.pedn.2023.11.011 37995477
- Addicks SH, McNeil DW. Randomized Controlled Trial of Motivational Interviewing to Support Breastfeeding Among Appalachian Women. J Obstet Gynecol Neonatal Nurs. 2019;48(4):418–32. PMID: 31181186. 10.1016/j.jogn.2019.05.003 31181186
- Anderson AK, Damio G, Young S, . A randomized trial assessing the efficacy of peer counseling on exclusive breastfeeding in a predominantly Latina low-income community. Arch Pediatr Adolesc Med. 2005;159(9):836–41. PMID: 16143742. 10.1001/archpedi.159.9.836 16143742
- Balaguer Martinez J, Valcarce PI, Esquivel OJ, . Telephone support for breastfeeding by primary care: a randomised multicentre trial. Anales de pediatria (Barcelona, Spain : 2003). 2018;89(6):344–51. PMID: 29576447. 10.1016/j.anpedi.2018.02.007 29576447
- Baransel ES, Caliskan BE. Effects of Face-to-Face Education Followed by Mobile Messaging to Primiparas on Maternal-Neonatal Care, Breastfeeding, and Motherhood Experience: A Randomized Controlled Trial. Z Geburtshilfe Neonatol. 2024;29:29. PMID: 38286412. 10.1055/a-2222-6568 38286412
- Bender W, Levine L, Durnwald C. Text Message-Based Breastfeeding Support Compared With Usual Care: A Randomized Controlled Trial. Obstet Gynecol. 2022;140(5):853–60. PMID: 36201773. 10.1097/aog.0000000000004961 36201773
- Bernal D. The effect of a peer counseling support program on breastfeeding initiation, duration and exclusivity among low-income Hispanic women. Doctoral clinical scholarly project. Brandman University; 2018.
- Bonuck K, Stuebe A, Barnett J, . Effect of primary care intervention on breastfeeding duration and intensity (BINGO). Am J Public Health. 2014_a;104 Suppl 1:S119–27. PMID: 24354834. 10.2105/AJPH.2013.301360 24354834
- Bonuck K, Stuebe A, Barnett J, . Effect of primary care intervention on breastfeeding duration and intensity (PAIRINGS). Am J Public Health. 2014_b;104 Suppl 1:S119–27. PMID: 24354834. 10.2105/AJPH.2013.301360 24354834
- Bonuck KA, Freeman K, Trombley M. Randomized controlled trial of a prenatal and postnatal lactation consultant intervention on infant health care use. Arch Pediatr Adolesc Med. 2006;160(9):953–60. PMID: 16953019. 10.1001/archpedi.160.9.953 16953019
  - Bonuck KA, Trombley M, Freeman K, . Randomized, controlled trial of a prenatal and postnatal lactation consultant intervention on duration and intensity of breastfeeding up to 12 months. Pediatrics. 2005;116(6):1413–26. PMID: 16322166. 10.1542/peds.2005-0435 16322166
- Bunik M, Jimenez-Zambrano A, Solano M, . Mother’s Milk Messaging TM: trial evaluation of app and texting for breastfeeding support. BMC Pregnancy Childbirth. 2022;22(1):660. PMID: 36002798. 10.1186/s12884-022-04976-6 36002798
- Bunik M, Shobe P, O’Connor ME, . Are 2 weeks of daily breastfeeding support insufficient to overcome the influences of formula? Acad Pediatr. 2010;10(1):21–8. PMID: 20129478. 10.1016/j.acap.2009.09.014 20129478
- Cangol E, Sahin NH. The Effect of a Breastfeeding Motivation Program Maintained During Pregnancy on Supporting Breastfeeding: A Randomized Controlled Trial. Breastfeed Med. 2017;12:218–26. PMID: 28287819. 10.1089/bfm.2016.0190 28287819
- Carlsen EM, Kyhnaeb A, Renault KM, . Telephone-based support prolongs breastfeeding duration in obese women: a randomized trial. Am J Clin Nutr. 2013;95(2):1226–32. PMID: 24004897. 10.3945/ajcn.113.059600 24004897
- Cauble JS, Herman A, Wick J, . A prenatal group based phone counseling intervention to improve breastfeeding rates and complementary feeding: a randomized, controlled pilot and feasibility trial. BMC Pregnancy Childbirth. 2021;21(1):521. PMID: 34294051. 10.1186/s12884-021-03976-2 34294051
- Chan MY, Ip WY, Choi KC. The effect of a self-efficacy-based educational programme on maternal breast feeding self-efficacy, breast feeding duration and exclusive breast feeding rates: A longitudinal study. Midwifery. 2016;36:92–8. PMID: 27106949. 10.1016/j.midw.2016.03.003 27106949
- Chapman DJ, Morel K, Bermudez-Millan A, . Breastfeeding education and support trial for overweight and obese women: a randomized trial. Pediatrics. 2013;131(1):e162–70. PMID: 23209111. 10.1542/peds.2012-0688 23209111
- Clarke JL, Ingram J, Johnson D, . The ABA intervention for improving breastfeeding initiation and continuation: Feasibility study results. Matern Child Nutr. 2020;16(1):e12907. PMID: 31793233. 10.1111/mcn.12907 31793233
  - Jolly K, Ingram J, Clarke J, . Protocol for a feasibility trial for improving breast feeding initiation and continuation: assets-based infant feeding help before and after birth (ABA). BMJ Open. 2018;8(1):e019142. PMID: 29362263. 10.1136/bmjopen-2017-019142 29362263
- Dennis CL, Hodnett E, Gallop R, . The effect of peer support on breast-feeding duration among primiparous women: a randomized controlled trial. CMAJ. 2002;166(1):21–8. PMID: 11800243.11800243
- Di Meglio G, McDermott MP, Klein JD. A randomized controlled trial of telephone peer support’s influence on breastfeeding duration in adolescent mothers. Breastfeed Med. 2010;5(1):41–7. PMID: 20043705. 10.1089/bfm.2009.0016 20043705
- Di Napoli A, Di Lallo D, Fortes C, . Home breastfeeding support by health professionals: findings of a randomized controlled trial in a population of Italian women. Acta Paediatr. 2004;93(8):1108–14. PMID: 15456204.15456204
- Edwards RC, Thullen MJ, Korfmacher J, . Breastfeeding and complementary food: randomized trial of community doula home visiting. Pediatrics. 2013;132 Suppl 2:S160–6. PMID: 24187119. 10.1542/peds.2013-1021P 24187119
- Ekambareshwar M, Mihrshahi S, Wen LM, . Facilitators and challenges in recruiting pregnant women to an infant obesity prevention programme delivered via telephone calls or text messages. Trials. 2018;19(1):494. PMID: 30219067. 10.1186/s13063-018-2871-5 30219067
- Elliott-Rudder M, Pilotto L, McIntyre E, . Motivational interviewing improves exclusive breastfeeding in an Australian randomised controlled trial. Acta Paediatr. 2014;103(1):e11–6. PMID: 24117857. 10.1111/apa.12434 24117857
- Fan HSL, Ho MY, Ko RWT, . Feasibility and effectiveness of WhatsApp online group on breastfeeding by peer counsellors: a single-blinded, open-label pilot randomized controlled study. Int Breastfeed J. 2022;17(1):91. PMID: 36544208. 10.1186/s13006-022-00535-z 36544208
  - Lok KY, Ko RW, Fan HS, . Feasibility and Acceptability of an Online WhatsApp Support Group on Breastfeeding: Protocol for a Randomized Controlled Trial. JMIR Res Protoc. 2022;11(3):e32338. PMID: 35262504. 10.2196/32338 35262504
- Fiks AG, Gruver RS, Bishop-Gilyard CT, . A Social Media Peer Group for Mothers To Prevent Obesity from Infancy: The Grow2Gether Randomized Trial. Child. 2017;13(5):356–68. PMID: 28557558. 10.1089/chi.2017.0042 28557558
  - Gruver RS, Bishop-Gilyard CT, Lieberman A, . A Social Media Peer Group Intervention for Mothers to Prevent Obesity and Promote Healthy Growth from Infancy: Development and Pilot Trial. JMIR Res Protoc. 2016;5(3):e159. PMID: 27485934. 10.2196/resprot.5276 27485934
- Forster D, McLachlan H, Lumley J, . Two mid-pregnancy interventions to increase the initiation and duration of breastfeeding: a randomized controlled trial. Birth. 2004;31(3):176–82. PMID: 15330879. 10.1111/j.0730-7659.2004.00302.x 15330879
- Forster DA, McLardie-Hore FE, McLachlan HL, . Proactive Peer (Mother-to-Mother) Breastfeeding Support by Telephone (Ringing up About Breastfeeding Early [RUBY]): A Multicentre, Unblinded, Randomised Controlled Trial. EClinicalMedicine. 2019;8:20–8. PMID: 31193656. 10.1016/j.eclinm.2019.02.003 31193656
  - Forster D, McLachlan H, Davey M-A, . Ringing Up about Breastfeeding: a randomised controlled trial exploring early telephone peer support for breastfeeding (RUBY) – trial protocol. BMC Pregnancy Childbirth. 2014;177. PMID: 24886264. 10.1186/1471-2393-14-177 24886264
  - Grimes HA, Forster DA, Shafiei T, . Breastfeeding peer support by telephone in the RUBY randomised controlled trial: A qualitative exploration of volunteers’ experiences. PLoS ONE. 2020;15(8):e0237190. PMID: 32760148. 10.1371/journal.pone.0237190 32760148
  - Grimes HA, McLachlan HL, Forster DA, . Implementing a successful proactive telephone breastfeeding peer support intervention: volunteer recruitment, training, and intervention delivery in the RUBY randomised controlled trial. Int Breastfeed J. 2021;16(1):90. PMID: 34852839. 10.1186/s13006-021-00434-9 34852839
  - Grimes HA, Shafiei T, McLachlan HL, . Volunteers’ experiences of providing telephone-based breast-feeding peer support in the RUBY randomised controlled trial. Public Health Nutr. 2020;23(16):3005–15. PMID: 32600489. 10.1017/S136898002000124X 32600489
  - McLardie-Hore FE, McLachlan HL, Shafiei T, . Proactive telephone-based peer support for breastfeeding: a cross-sectional survey of women’s experiences of receiving support in the RUBY randomised controlled trial. BMJ Open. 2020;10(10):e040412. PMID: 33127637. 10.1136/bmjopen-2020-040412 33127637
- Franco-Antonio C, Calderon-Garcia JF, Santano-Mogena E, . Effectiveness of a brief motivational intervention to increase the breastfeeding duration in the first 6 months postpartum: Randomized controlled trial. J Adv Nurs. 2020;76(3):888–902. PMID: 31782535. 10.1111/jan.14274 31782535
  - Franco-Antonio C, Calderon-Garcia JF, Vilar-Lopez R, . A randomized controlled trial to evaluate the effectiveness of a brief motivational intervention to improve exclusive breastfeeding rates: Study protocol. J Adv Nurs. 2018;75(4):888–97. PMID: 30478855. 10.1111/jan.13917 30478855
  - Franco-Antonio C, Santano-Mogena E, Chimento-Diaz S, . A randomised controlled trial evaluating the effect of a brief motivational intervention to promote breastfeeding in postpartum depression. Sci. 2022;12(1):373. PMID: 35013506. 10.1038/s41598-021-04338-w 35013506
- Fu I, Fong D, Heys M, . Professional breastfeeding support for first-time mothers: a multicentre cluster randomised controlled trial. Bjog. 2014;121(13):1673–83. PMID: 24861802. 10.1111/1471-0528.12884 24861802
- Gagnon AJ, Dougherty G, Jimenez V, . Randomized trial of postpartum care after hospital discharge. Pediatrics. 2002;109(6):1074–80. PMID: 12042545. 10.1542/peds.109.6.1074 12042545
- Gijsbers B, Mesters I, Knottnerus JA, . The Success of an Educational Program to Promote Exclusive Breastfeeding for 6 Months in Families with a History of Asthma: A Randomized Controlled Trial. Pediatric Asthma, Allergy & Immunology. 2006;19(4):214–22. 10.1089/pai.2006.19.214
  - Mesters I, Gijsbers B, Bartholomew K, . Social cognitive changes resulting from an effective breastfeeding education program. Breastfeed Med. 2013;8(1):23–30. PMID: 23186384. 10.1089/bfm.2012.0011 23186384
- Graffy J, Taylor J, Williams A, . Randomised controlled trial of support from volunteer counsellors for mothers considering breast feeding. Bmj. 2004;328(7430):26. PMID: 14703543. 10.1136/bmj.328.7430.26 14703543
- Gross RS, Mendelsohn AL, Gross MB, . Randomized Controlled Trial of a Primary Care-Based Child Obesity Prevention Intervention on Infant Feeding Practices. Journal of Pediatrics. 2016;174:171–7.e2. PMID: 27113376. 10.1016/j.jpeds.2016.03.060 27113376
  - Messito MJ, Katzow MW, Mendelsohn AL, . Starting Early Program Impacts on Feeding at Infant 10 Months Age: A Randomized Controlled Trial. Child. 2020;16:S-4–S-13. PMID: 145363138. 10.1089/chi.2019.0236
- Hans SL, Edwards RC, Zhang Y. Randomized Controlled Trial of Doula-Home-Visiting Services: Impact on Maternal and Infant Health. Maternal & Child Health Journal. 2018;22(Suppl 1):105–13. PMID: 29855838. 10.1007/s10995-018-2537-7 29855838
- Henderson A, Stamp G, Pincombe J. Postpartum positioning and attachment education for increasing breastfeeding: a randomized trial. Birth. 2001;28(4):236–42. PMID: 11903211. 10.1046/j.1523-536x.2001.00236.x 11903211
- Hoffmann J, Gunther J, Stecher L, . Effects of a lifestyle intervention in routine care on short-and long-term maternal weight retention and breastfeeding behavior - 12 months follow-up of the cluster-randomized gelis trial. J Clin Med. 2019;8(6). PMID: 31248138. 10.3390/jcm8060876 31248138
  - Günther J, Hoffmann J, Kunath J, . Effects of a Lifestyle Intervention in Routine Care on Prenatal Dietary Behavior-Findings from the Cluster-Randomized GeliS Trial. J Clin Med. 2019;8(7). PMID: 31269753. 10.3390/jcm8070960 31269753
  - Hoffmann J, Günther J, Geyer K, . Effects of a lifestyle intervention in routine care on prenatal physical activity - findings from the cluster-randomised GeliS trial. BMC Pregnancy Childbirth. 2019;19(1):414. PMID: 31711430. 10.1186/s12884-019-2553-7 31711430
  - Kunath J, Günther J, Rauh K, . Effects of a lifestyle intervention during pregnancy to prevent excessive gestational weight gain in routine care - the cluster-randomised GeliS trial. BMC Med. 2019;17(1):5. PMID: 30636636. 10.1186/s12916-018-1235-z 30636636
  - Rauh K, Kunath J, Rosenfeld E, . Healthy living in pregnancy: a cluster-randomized controlled trial to prevent excessive gestational weight gain - rationale and design of the GeliS study. BMC Pregnancy Childbirth. 2014;14:119. PMID: 24678761. 10.1186/1471-2393-14-119 24678761
- Hopkinson J, Konefal Gallagher M. Assignment to a hospital-based breastfeeding clinic and exclusive breastfeeding among immigrant Hispanic mothers: a randomized, controlled trial. J Hum Lact. 2009;25(3):287–96. PMID: 19436060. 10.1177/0890334409335482 19436060
- Howell EA, Bodnar-Deren S, Balbierz A, . An intervention to extend breastfeeding among black and Latina mothers after delivery. Am J Obstet Gynecol. 2014;210(3):239.e1–5. PMID: 24262719. 10.1016/j.ajog.2013.11.028 24262719
  - Howell EA, Balbierz A, Wang J, . Reducing postpartum depressive symptoms among black and Latina mothers: a randomized controlled trial. Obstet Gynecol. 2012;119(5):942–9. PMID: 22488220. 10.1097/AOG.0b013e318250ba48 22488220
- Jolly K, Ingram L, Freemantle N, . Effect of a peer support service on breast-feeding continuation in the UK: A randomised controlled trial. Midwifery. 2012;28(6):740–5. PMID: 21944571. 10.1016/j.midw.2011.08.005 21944571
  - MacArthur C, Jolly K, Ingram L, . Antenatal peer support workers and initiation of breast feeding: Cluster randomised controlled trial. Bmj. 2009;338(7691):No Pagination Specified. PMID: 19181730. 10.1136/bmj.b131 19181730
- Karaahmet AY, Bilgic FS. Breastfeeding success in the first 6 months of online breastfeeding counseling after cesarean delivery and its effect on anthropometric measurements of the baby: a randomized controlled study. Rev Assoc Med Bras. 2022;68(10):1434–40. PMID: 36417649. 10.1590/1806-9282.20220540 36417649
- Kellams AL, Gurka KK, Hornsby PP, . The Impact of a Prenatal Education Video on Rates of Breastfeeding Initiation and Exclusivity during the Newborn Hospital Stay in a Low-income Population. J Hum Lact. 2015. PMID: 26289058. 10.1177/0890334415599402 26289058
  - Hornsby PP, Gurka KK, Conaway MR, . Reasons for Early Cessation of Breastfeeding Among Women with Low Income. Breastfeed Med. 2019;14(6):375–81. PMID: 30994371. 10.1089/bfm.2018.0206 30994371
  - Kellams AL, Gurka KK, Hornsby PP, . A Randomized Trial of Prenatal Video Education to Improve Breastfeeding Among Low-Income Women. Breastfeed Med. 2018;13(10):666–73. PMID: 30351169. 10.1089/bfm.2018.0115 30351169
- Kenyon S, Jolly K, Hemming K, . Lay support for pregnant women with social risk: a randomised controlled trial. BMJ Open. 2016;6(3):e009203. PMID: 26936901. 10.1136/bmjopen-2015-009203 26936901
- Kools EJ, Thijs C, Kester AD, . A breast-feeding promotion and support program a randomized trial in The Netherlands. Prev Med. 2005;40(1):60–70. PMID: 15530582. 10.1016/j.ypmed.2004.05.013 15530582
- Kronborg H, Maimburg RD, Vaeth M. Antenatal training to improve breast feeding: a randomised trial. Midwifery. 2012;28(6):784–90. PMID: 22018394. 10.1016/j.midw.2011.08.016 22018394
- Labarere J, Bellin V, Fourny M, . Assessment of a structured in-hospital educational intervention addressing breastfeeding: a prospective randomised open trial. Bjog. 2003;110(9):847–52. PMID: 14511968.14511968
- Labarere J, Gelbert-Baudino N, Ayral AS, . Efficacy of breastfeeding support provided by trained clinicians during an early, routine, preventive visit: a prospective, randomized, open trial of 226 mother-infant pairs. Pediatrics. 2005;115(2):e139–e46. PMID: 15687421. 10.1542/peds.2004-1362 15687421
- Laliberte C, Dunn S, Pound C, . A randomized controlled trial of innovative postpartum care model for mother-baby dyads. PLoS ONE. 2016;11(2) (no pagination). PMID: 26871448. 10.1371/journal.pone.0148520 26871448
- Lavender T, Baker L, Smyth R, . Breastfeeding expectations versus reality: a cluster randomised controlled trial. Bjog. 2005;112(8):1047–53. PMID: 16045516. 10.1111/j.1471-0528.2005.00644.x 16045516
- Lewkowitz AK, Lopez JD, Carter EB, . Impact of a novel smartphone application on low-income, first-time mothers’ breastfeeding rates: a randomized controlled trial. Am J Obstet Gynecol MFM. 2020;2(3):100143. PMID: 33345878. 10.1016/j.ajogmf.2020.100143 33345878
  - Griffin LB, Lopez JD, Ranney ML, . Effect of Novel Breastfeeding Smartphone Applications on Breastfeeding Rates. Breastfeed Med. 2021;16(8):614–23. PMID: 33826418. 10.1089/bfm.2021.0012 33826418
  - Lewkowitz AK, Lopez JD, Werner EF, . Effect of a Novel Smartphone Application on Breastfeeding Rates Among Low-Income, First-Time Mothers Intending to Exclusively Breastfeed: Secondary Analysis of a Randomized Controlled Trial. Breastfeed Med. 2021;16(1):59–67. PMID: 33085510. 10.1089/bfm.2020.0240 33085510
- Lewkowitz AK, Lopez JD, Stein RI, . Effect of a Home-Based Lifestyle Intervention on Breastfeeding Initiation Among Socioeconomically Disadvantaged African American Women with Overweight or Obesity. Breastfeed Med. 2018;13(6):418–25. PMID: 29912571. 10.1089/bfm.2018.0006 29912571
  - Cahill AG, Haire-Joshu D, Cade WT, . Weight Control Program and Gestational Weight Gain in Disadvantaged Women with Overweight or Obesity: A Randomized Clinical Trial. Obesity (Silver Spring). 2018;26(3):485–91. PMID: 29464907. 10.1002/oby.22070 29464907
- Linares AM, Cartagena D, Rayens MK. Las Dos Cosas Versus Exclusive Breastfeeding: A Culturally and Linguistically Exploratory Intervention Study in Hispanic Mothers Living in Kentucky. Journal of Pediatric Health Care. 2019;33(6):e46–e56. PMID: 31655788. 10.1016/j.pedhc.2019.07.009 31655788
- Little EE, Cioffi CC, Bain L, . An Infant Carrier Intervention and Breastfeeding Duration: A Randomized Controlled Trial. Pediatrics. 2021;148(1):07. PMID: 34193622. 10.1542/peds.2020-049717 34193622
- Lucas R, Zhang Y, Walsh SJ, . Efficacy of a Breastfeeding Pain Self-Management Intervention: A Pilot Randomized Controlled Trial. Nursing Research. 2019;68(2):E1–E10. PMID: 30829925. 10.1097/NNR.0000000000000336 30829925
- Lucchini-Raies C, Marquez-Doren F, Beca P, . The CRIAA Program complex intervention in primary care to support women and their families in breastfeeding: Study protocol for a pilot trial. J Adv Nurs. 2020;76(12):3641–53. PMID: 33058232. 10.1111/jan.14534 33058232
- Lutenbacher M, Elkins T, Dietrich MS. Using Community Health Workers to Improve Health Outcomes in a Sample of Hispanic Women and Their Infants: Findings from a Randomized Controlled Trial. Hisp Health Care Int. 2023:21 (3):129–141. PMID: 35702003. 10.1177/15404153221107680 35702003
- Mattar CN, Chong YS, Chan YS, . Simple antenatal preparation to improve breastfeeding practice: a randomized controlled trial. Obstet Gynecol. 2007;109(1):73–80. PMID: 17197590. 10.1097/01.AOG.0000249613.15466.26 17197590
- McDonald SJ, Henderson JJ, Faulkner S, . Effect of an extended midwifery postnatal support programme on the duration of breast feeding: a randomised controlled trial. Midwifery. 2010;26(1):88–100. PMID: 18486287. 10.1016/j.midw.2008.03.001 18486287
- McLachlan HL, Forster DA, Amir LH, . Supporting breastfeeding In Local Communities (SILC) in Victoria, Australia: a cluster randomised controlled trial. BMJ Open. 2016;6(2):e008292. PMID: 26832427. 10.1136/bmjopen-2015-008292 26832427
  - McLachlan HL, Forster DA, Amir LH, . Supporting breastfeeding In Local Communities (SILC): protocol for a cluster randomised controlled trial. BMC Pregnancy Childbirth. 2014;14:346. PMID: 25281300. 10.1186/1471-2393-14-346 25281300
  - Ridgway L, Cramer R, McLachlan HL, . Breastfeeding Support in the Early Postpartum: Content of Home Visits in the SILC Trial. Birth. 2016;43(4):303–12. PMID: 27417659. 10.1111/birt.12241 27417659
- McQueen KA, Dennis CL, Stremler R, . A pilot randomized controlled trial of a breastfeeding self-efficacy intervention with primiparous mothers. J Obstet Gynecol Neonatal Nurs. 2011;40(1):35–46. PMID: 21244493. 10.1111/j.1552-6909.2010.01210.x 21244493
- Milinco M, Travan L, Cattaneo A, . Effectiveness of biological nurturing on early breastfeeding problems: a randomized controlled trial. Int Breastfeed J. 2020;15(1):21. PMID: 32248838. 10.1186/s13006-020-00261-4 32248838
- Miremberg H, Yirmiya K, Rona S, . Smartphone-based counseling and support platform and the effect on postpartum lactation: a randomized controlled trial. Am J Obstet Gynecol MFM. 2022;4(2):100543. PMID: 34871782. 10.1016/j.ajogmf.2021.100543 34871782
- Mottl-Santiago J, Dukhovny D, Cabral H, . Effectiveness of an Enhanced Community Doula Intervention in a Safety Net Setting: A Randomized Controlled Trial. Health Equity. 2023;7(1):466–76. PMID: 37731785. 10.1089/heq.2022.0200 37731785
- Muirhead PE, Butcher G, Rankin J, . The effect of a programme of organised and supervised peer support on the initiation and duration of breastfeeding: a randomised trial. Br J Gen Pract. 2006;56(524):191–7. PMID: 16536959.16536959
- Nilsson IMS, Strandberg-Larsen K, Knight CH, . Focused breastfeeding counselling improves short- and long-term success in an early-discharge setting: A cluster-randomized study. Matern Child Nutr. 2017;13(4):10. PMID: 28194877. 10.1111/mcn.12432 28194877
- Noel-Weiss J, Rupp A, Cragg B, . Randomized controlled trial to determine effects of prenatal breastfeeding workshop on maternal breastfeeding self-efficacy and breastfeeding duration. J Obstet Gynecol Neonatal Nurs. 2006;35(5):616–24. PMID: 16958717. 10.1111/j.1552-6909.2006.00077.x 16958717
  - Noel-Weiss J, Bassett V, Cragg B. Developing a prenatal breastfeeding workshop to support maternal breastfeeding self-efficacy. J Obstet Gynecol Neonatal Nurs. 2006;35(3):349–57. PMID: 16700684. 10.1111/j.1552-6909.2006.00053.x 16700684
- O’Reilly SL, McNestry C, McGuinness D, . Multicomponent perinatal breastfeeding support in women with BMI >25: The Latch On multi-centre randomised trial. BJOG: An International Journal of Obstetrics & Gynaecology. 2024;12:12. PMID: 38344894. 10.1111/1471-0528.17782 38344894
  - O’Reilly SL, O’Brien EC, McGuinness D, . Latch On: A protocol for a multi-centre, randomised controlled trial of perinatal support to improve breastfeeding outcomes in women with a raised BMI. Contemp Clin Trials Commun. 2021;22:100767. PMID: 34095603. 10.1016/j.conctc.2021.100767 34095603
- Paul IM, Beiler JS, Schaefer EW, . A randomized trial of single home nursing visits vs office-based care after nursery/maternity discharge: the Nurses for Infants Through Teaching and Assessment After the Nursery (NITTANY) Study. Arch Pediatr Adolesc Med. 2012;166(3):263–70. PMID: 22064874. 10.1001/archpediatrics.2011.198 22064874
- Pollard DL. Impact of a feeding log on breastfeeding duration and exclusivity. Matern Child Health J. 2011;15(3):395–400. PMID: 20177755. 10.1007/s10995-010-0583-x 20177755
- Puharic D, Malicki M, Borovac JA, . The effect of a combined intervention on exclusive breastfeeding in primiparas: A randomised controlled trial. Matern Child Nutr. 2020;16(3):e12948. PMID: 31943761. 10.1111/mcn.12948 31943761
  - Zakarija-Grkovic I, Puharic D, Malicki M, . Breastfeeding booklet and proactive phone calls for increasing exclusive breastfeeding rates: RCT protocol. Matern Child Nutr. 2017;13(1):01. PMID: 26990672. 10.1111/mcn.12249 26990672
- Quinlivan JA, Box H, Evans SF. Postnatal home visits in teenage mothers: a randomised controlled trial. Lancet. 2003;361(9361):893–900. PMID: 12648967. 10.1016/S0140-6736(03)12770-5 12648967
- Reeder JA, Joyce T, Sibley K, . Telephone peer counseling of breastfeeding among WIC participants: a randomized controlled trial. Pediatrics. 2014;134(3):e700–9. PMID: 25092936. 10.1542/peds.2013-4146 25092936
- Saglik M, Karacam Z. Effectiveness of structured education and follow-up in the management of perceived breastmilk insufficiency: a randomized control trial. Health Care Women Int. 2021:1–19. PMID: 34919025. 10.1080/07399332.2021.2007249 34919025
- Santamaria-Martin MJ, Martin-Iglesias S, Schwarz C, . Effectiveness of a group educational intervention - prolact - in primary care to promote exclusive breastfeeding: a cluster randomized clinical trial. BMC Pregnancy Childbirth. 2022;22(1):132. PMID: 35172775. 10.1186/s12884-022-04394-8 35172775
  - Martin-Iglesias S, Santamaria-Martin MJ, Alonso-Alvarez A, . Effectiveness of an educational group intervention in primary healthcare for continued exclusive breast-feeding: PROLACT study. BMC Pregnancy Childbirth. 2018;18(1):59. PMID: 29482516. 10.1186/s12884-018-1679-3 29482516
- Sari C, Altay N. Effects of providing nursing care with web-based program on maternal self-efficacy and infant health. Public Health Nurs. 2020;37(3):380–92. PMID: 32017251. 10.1111/phn.12712 32017251
- Sari Ozturk C, Demir K. The Effect of Mandala Activity and Technology-Based Breastfeeding Program on Breastfeeding Self-Efficacy and Mother-Infant Attachment of Primiparous Women: A Randomized Controlled Study. J Med Syst. 2023;47(1):44. PMID: 37004692. 10.1007/s10916-023-01942-3 37004692
- Saucedo Baza A, Mignacca C, Delgado PE, . A Technological Approach to Improved Breastfeeding Rates and Self-Efficacy: A Randomized Controlled Pilot Study. J Hum Lact. 2023;39(4):679–87. PMID: 37571838. 10.1177/08903344231190625 37571838
- Schwarz EB, Hoyt-Austin A, Fix M, . Prenatal Counseling on the Maternal Health Benefits of Lactation: A Randomized Trial. Breastfeed Med. 2024;19(1):52–8. PMID: 38190278. 10.1089/bfm.2023.0219 38190278 Sevda KO, Sevil I. Continuous Lactation Support Provided Through the WhatsApp Messaging Application: A Randomized Controlled Trial. J Hum Lact. 2023;39(4):666–78. PMID: 37646262. 10.1177/08903344231192948 37646262
- Simsek-Cetinkaya S, Gumus Calis G, Kibris S. Effect of Breastfeeding Education Program and Nurse-led Breastfeeding Online Counseling System (BMUM) for Mothers: A Randomized Controlled Study. J Hum Lact. 2024;40(1):101–12. PMID: 38006250. 10.1177/08903344231210813 38006250
- Stockdale J, Sinclair M, Kernohan WG, . Feasibility study to test DESIGNER BREASTFEEDING: a randomised controlled trial. Evidence Based Midwifery. 2008;6(3):76–82.
- Su LL, Chong YS, Chan YH, . Antenatal education and postnatal support strategies for improving rates of exclusive breast feeding: randomised controlled trial. Bmj. 2007;335(7620):596. PMID: 17670909. 10.1136/bmj.39279.656343.55 17670909
- Taylor B, Gray A, Galland B, . Targeting sleep, food, and activity in infants for obesity prevention: an RCT. Pediatrics. 2017;139(3) (no pagination). PMID: 28242860. 10.1542/peds.2016-2037 28242860
- Uscher-Pines L, Ghosh-Dastidar B, Bogen DL, . Feasibility and Effectiveness of Telelactation Among Rural Breastfeeding Women. Academic pediatrics. 2020;20(5):652–9. PMID: 31629118. 10.1016/j.acap.2019.10.008 31629118
- Wallace LM, Dunn OM, Alder EM, . A randomised-controlled trial in England of a postnatal midwifery intervention on breast-feeding duration. Midwifery. 2006;22(3):262–73. PMID: 16380197. 10.1016/j.midw.2005.06.004 16380197
- Wambach KA, Aaronson L, Breedlove G, . A randomized controlled trial of breastfeeding support and education for adolescent mothers. West J Nurs Res. 2011;33(4):486–505. PMID: 20876551. 10.1177/0193945910380408 20876551
- Wen LM, Baur LA, Simpson JM, . Effectiveness of an early intervention on infant feeding practices and “tummy time”: a randomized controlled trial. Arch Pediatr Adolesc Med. 2011;165(8):701–7. PMID: 21810633. 10.1001/archpediatrics.2011.115 21810633
  - Wen LM, Baur LA, Rissel C, . Early intervention of multiple home visits to prevent childhood obesity in a disadvantaged population: a home-based randomised controlled trial (Healthy Beginnings Trial). BMC Public Health. 2007;7:76. PMID: 17490492. 10.1186/1471-2458-7-76 17490492
- Wen LM, Rissel C, Xu H, . Effects of Telephone and Short Message Service Support on Infant Feeding Practices, “Tummy Time,” and Screen Time at 6 and 12 Months of Child Age: A 3-Group Randomized Clinical Trial. JAMA Pediatrics. 2020;174(7):657–64. PMID: 32282034. 10.1001/jamapediatrics.2020.0215 32282034
  - Owen-Jones E, Bekkers MJ, Butler CC, . The effectiveness and cost-effectiveness of the Family Nurse Partnership home visiting programme for first time teenage mothers in England: a protocol for the Building Blocks randomised controlled trial. BMC Pediatr. 2013;13:114. PMID: 23919573. 10.1186/1471-2431-13-114 23919573
  - Wen LM, Rissel C, Baur LA, . A 3-Arm randomised controlled trial of Communicating Healthy Beginnings Advice by Telephone (CHAT) to mothers with infants to prevent childhood obesity. BMC Public Health. 2017;17(1):79. PMID: 28088203. 10.1186/s12889-016-4005-x 28088203
- Wong KL, Tak Fong DY, Yin Lee IL, . Antenatal education to increase exclusive breastfeeding: a randomized controlled trial. Obstet Gynecol. 2014;124(5):961–8. PMID: 25437725. 10.1097/AOG.0000000000000481 25437725
- Yesil Y, Ekşioğlu A, Turfan EC. The effect of hospital-based breastfeeding group education given early perinatal period on breastfeeding self-efficacy and breastfeeding status. Journal of Neonatal Nursing. 2023;29(1):81–90. 10.1016/j.jnn.2022.02.013