# Appendix B Literature Flow Diagram

Appendix B Figure 1 Literature Flow Diagram

Abbreviation: BF = breastfeeding.