# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

Original search – Date delivered 3/29/22

Bridge1 – Date delivered 5/12/23

Bridge2 - Date delivered 6/3/24

Sources Searched: database and platform Search dates 2015-June 3, 2024
MEDLINE via Ovid
PsycInfo via Ovid
Cochrane Central Register of Controlled Clinical Trials via Wiley
CINAHL via Ebsco

While running the second bridge a typo had been identified that had been replicated in each database search, going back to the 2015 review. ‘atenatal’ was used when ‘antenatal’ should have been used: Medline line 28, PsycInfo line 25, Cochrane line 11, CINAHL line S2.

The search was modified, the misspelling was removed, and lines were added to capture the correct spelling with no limits on dates.

Search filters used:

RCT:

- Chris Cooper, Jo Varley-Campbell and Patrice Carter, Established search filters may miss studies when identifying randomized controlled trials, Journal of Clinical Epidemiology, 2019-08-01, Volume 112, Pages 12–19 30986533
- Glanville JM, Lefebvre C, Miles JN, Camosso-Stefinovic J. How to identify randomized controlled trials in MEDLINE: ten years on. Journal of the Medical Library Association 2006; 94: 130–136. https://www.ncbi.nlm.nih.gov/pmc/articles/PMC1435857/ 16636704
- Box 3.d Cochrane Highly Sensitive Search Strategy for identifying randomized trials in MEDLINE: sensitivity- and precision-maximizing version (2008 revision); Ovid format from: Lefebvre C, Glanville J, Briscoe S, Littlewood A, Marshall C, Metzendorf M-I, Noel-Storr A, Rader T, Shokraneh F, Thomas J, Wieland LS. Chapter 4: Searching for and selecting studies. In: Higgins JPT, Thomas J, Chandler J, Cumpston M, Li T, Page MJ, Welch VA (editors). Cochrane Handbook for Systematic Reviews of Interventions version 6.2 (updated February 2021). Cochrane, 2021. Available from www.training.cochrane.org/handbook
- Glanville J, Dooley G, Wisniewski S, Foxlee R, Noel-Storr A. Development of a search filter to identify reports of controlled clinical trials within CINAHL Plus. Health Info Libr J. 2019 Mar;36(1):73–90. doi: 10.1111/hir.12251. Epub 2019 Feb 8. PMID: 30737884.30737884

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- pt = publication type
- * = truncation
- kw = keyword

### MEDLINE via Ovid

Database: Ovid MEDLINE(R) ALL <1946 to March 28, 2022>

Search Strategy:

--------------------------------------------------------------------------------

1. Breast feeding/ (41475)
2. Milk, Human/ (21372)
3. Breast Milk Expression/ (378)
4. Lactation/ (45545)
5. (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti,kf. (38234)
6. (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti,ab,kf. (85938)
7. limit 6 to (“in data review” or in process or “pubmed not medline”) (7143)
8. or/1-5,7 (104697)
9. Health Promotion/ (78958)
10. Health Education/ (62735)
11. Patient Education as Topic/ (87984)
12. Social Support/ (76308)
13. Counseling/ (38350)
14. Motivational Interviewing/ (2335)
15. Prenatal Education/ (321)
16. Education, Medical/ (59702)
17. Kangaroo-Mother Care Method/ (631)
18. Attitude of Health Personnel/ (129221)
19. Organizational Policy/ (14489)
20. Program development/ (30190)
21. Pacifiers/ (528)
22. motivational interview$.ti,ab,kf. (5030)
23. peer counsel$.ti,ab,kf. (613)
24. group counsel$.ti,ab,kf. (813)
25. social$ support$.ti,ab,kf. (48425)
26. home visit$.ti,ab,kf. (10112)
27. ((staff or nurs$ or midwife$ or midwives or doula$ or doctor$ or physician$ or obstetrician$ or p?ediatrician$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,kf. (133609)
28. ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth$ or child birth$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,kf. (3917)
29. (kangaroo adj3 care).ti,ab,kf. (940)
30. baby friendly.ti,ab,kf. (1021)
31. skin to skin.ti,ab,kf. (6818)
32. pacifier$.ti,ab,kf. (1179)
33. ((breast feed$ or breast fed or breastfeed$ or breastfed or lactation) adj on demand).ti,ab,kf. (102)
34. rooming in.ti,ab,kf. (793)
35. ((hospital$ or health system$ or health care system$) adj3 (policy or policies or initiative$ or program$ or practice$)).ti,ab,kf. (28789)
36. (express$ adj2 (breastmilk or breast milk)).ti,ab,kf. (718)
37. or/9-36 (705972)
38. 8 and 37 (9846)
39. ((incr$ or improv$ or support$ or promot$ or encourag$ or counsel$ or educat$ or train$ or teach$ or class$ or facilitat$ or rate or rates) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,kf. (17585)
40. ((intervention$ or program$ or clinic or clinics or policy or policies or plan$) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,kf. (4307)
41. lactation consult$.ti,ab,kf. (506)
42. or/38-41 (23879)
43. limit 42 to (english language and yr=“2015 -Current”) (8652)
44. 43 not (animals/ not humans/) (7865)
45. (randomized controlled trial or controlled clinical trial or clinical trial).pt. or clinical trials as topic/ or exp Randomized Controlled Trials as Topic/ or (randomized or randomised or placebo or randomly or phase iii or phase 3 or controlled trial).ti,ab. or trial.ti. (1760369)
46. control groups/ or double-blind method/ or single-blind method/ (203405)
47. (RCT or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or random$ or control group).ti,ab. not medline.st. (249982)
48. 45 or 46 or 47 (1890318)
49. 44 and 48 (1296)

#### Medline via Ovid – bridge 2023

Ovid MEDLINE(R) ALL <1946 to May 11, 2023>

1. Breast feeding/ 43533
2. Milk, Human/ 22476
3. Breast Milk Expression/ 389
4. Lactation/ 47490
5. (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti,kf. 40829
6. (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti,ab,kf. 91659
7. limit 6 to (“in data review” or in process or “pubmed not medline”) 8241
8. or/1-5,7 110243
9. Health Promotion/ 81107
10. Health Education/ 63550
11. Patient Education as Topic/ 88260
12. Social Support/ 78535
13. Counseling/ 39574
14. Motivational Interviewing/ 2540
15. Prenatal Education/ 345
16. Education, Medical/ 60904
17. Kangaroo-Mother Care Method/ 726
18. Attitude of Health Personnel/ 131204
19. Organizational Policy/ 14520
20. Program development/ 30294
21. Pacifiers/ 550
22. motivational interview$.ti,ab,kf. 5544
23. peer counsel$.ti,ab,kf. 650
24. group counsel$.ti,ab,kf. 877
25. social$ support$.ti,ab,kf. 54269
26. home visit$.ti,ab,kf. 10850
27. ((staff or nurs$ or midwife$ or midwives or doula$ or doctor$ or physician$ or obstetrician$ or p?ediatrician$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,kf. 142826
28. ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth$ or child birth$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,kf. 4225
29. (kangaroo adj3 care).ti,ab,kf. 1090
30. baby friendly.ti,ab,kf. 1091
31. skin to skin.ti,ab,kf. 7429
32. pacifier$.ti,ab,kf. 1242
33. ((breast feed$ or breast fed or breastfeed$ or breastfed or lactation) adj on demand).ti,ab,kf. 107
34. rooming in.ti,ab,kf. 847
35. ((hospital$ or health system$ or health care system$) adj3 (policy or policies or initiative$ or program$ or practice$)).ti,ab,kf. 30867
36. (express$ adj2 (breastmilk or breast milk)).ti,ab,kf. 784
37. or/9-36 732505
38. 8 and 37 10336
39. ((incr$ or improv$ or support$ or promot$ or encourag$ or counsel$ or educat$ or train$ or teach$ or class$ or facilitat$ or rate or rates) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,kf. 18948
40. ((intervention$ or program$ or clinic or clinics or policy or policies or plan$) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,kf. 4698
41. lactation consult$.ti,ab,kf. 545
42. or/38-41 25538
43. limit 42 to (english language and yr=“2015 -Current”) 10295
44. 43 not (animals/ not humans/) 9416
45. (randomized controlled trial or controlled clinical trial or clinical trial).pt. or clinical trials as topic/ or exp Randomized Controlled Trials as Topic/ or (randomized or randomised or placebo or randomly or phase iii or phase 3 or controlled trial).ti,ab. or trial.ti. 1855278
46. control groups/ or double-blind method/ or single-blind method/ 208625
47. (RCT or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or random$ or control group).ti,ab. not medline.st. 283523
48. 45 or 46 or 47 2002571
49. 44 and 48 1536
50. (202202* or 202203* or 202204* or 202205* or 202206* or 202207* or 202208* or 202209* or 202210* or 202211* or 202212* or 2023*).dt,da,ez. 2422777
51. 49 and 50 313

#### Medline via Ovid – bridge 2024

Ovid MEDLINE(R) ALL <1946 to May 30, 2024>

1. Breast feeding/ 45110
2. Milk, Human/ 23406
3. Breast Milk Expression/ 407
4. Lactation/ 49176
5. (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti,kf. 43326
6. (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti,ab,kf. 96879
7. limit 6 to (“in data review” or in process or “pubmed not medline”) 9661
8. or/1-5,7 115499
9. Health Promotion/ 82900
10. Health Education/ 64291
11. Patient Education as Topic/ 88702
12. Social Support/ 80332
13. Counseling/ 40548
14. Motivational Interviewing/ 2690
15. Prenatal Education/ 365
16. Education, Medical/ 62076
17. Kangaroo-Mother Care Method/ 810
18. Attitude of Health Personnel/ 133184
19. Organizational Policy/ 14550
20. Program development/ 30403
21. Pacifiers/ 559
22. motivational interview$.ti,ab,kf. 6029
23. peer counsel$.ti,ab,kf. 689
24. group counsel$.ti,ab,kf. 938
25. social$ support$.ti,ab,kf. 59410
26. home visit$.ti,ab,kf. 11480
27. ((staff or nurs$ or midwife$ or midwives or doula$ or doctor$ or physician$ or obstetrician$ or p?ediatrician$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,kf. 151927
28. ((prenatal or pre natal or postnatal or post natal or ante natal or childbirth$ or child birth$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,kf. 4500
29. (kangaroo adj3 care).ti,ab,kf. 1183
30. baby friendly.ti,ab,kf. 1142
31. skin to skin.ti,ab,kf. 7994
32. pacifier$.ti,ab,kf. 1290
33. ((breast feed$ or breast fed or breastfeed$ or breastfed or lactation) adj on demand).ti,ab,kf. 111
34. rooming in.ti,ab,kf. 883
35. ((hospital$ or health system$ or health care system$) adj3 (policy or policies or initiative$ or program$ or practice$)).ti,ab,kf. 32695
36. (express$ adj2 (breastmilk or breast milk)).ti,ab,kf. 841
37. or/9-36 757218
38. 8 and 37 10753
39. ((incr$ or improv$ or support$ or promot$ or encourag$ or counsel$ or educat$ or train$ or teach$ or class$ or facilitat$ or rate or rates) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,kf. 20307
40. ((intervention$ or program$ or clinic or clinics or policy or policies or plan$) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,kf. 5084
41. lactation consult$.ti,ab,kf. 588
42. or/38-41 27164
43. limit 42 to (english language and yr=“2015 -Current”) 11872
44. 43 not (animals/ not humans/) 10896
45. (randomized controlled trial or controlled clinical trial or clinical trial).pt. or clinical trials as topic/ or exp Randomized Controlled Trials as Topic/ or (randomized or randomised or placebo or randomly or phase iii or phase 3 or controlled trial).ti,ab. or trial.ti. 1944356
46. control groups/ or double-blind method/ or single-blind method/ 213222
47. (RCT or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or random$ or control group).ti,ab. not medline.st. 328079
48. 45 or 46 or 47 2113585
49. 44 and 48 1786
50. (202304* or 202305* or 202306* or 202307* or 202308* or 202309* or 20231* or 2024*).dt,da,ez. 1993988
51. 49 and 50 298
52. (antenatal adj5 (train$ or educat$ or teach$ or class$)).ti,ab,kf. 2108
53. 52 not 37 1280
54. 8 and 48 and 53 11
55. 51 or 54 306

#### PsycInfo via Ovid

Database: APA PsycInfo <1806 to March Week 3 2022>

Search Strategy:

--------------------------------------------------------------------------------

1. Breast Feeding/ (3900)
2. Lactation/ (1639)
3. (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti,ab,id. (8459)
4. 1 or 2 or 3 (9124)
5. Health Promotion/ (26945)
6. Counseling/ (24668)
7. Counselors/ (8846)
8. Motivational Interviewing/ (2819)
9. Client Education/ (4351)
10. Health Education/ (14113)
11. Childbirth Training/ (234)
12. Support Groups/ (4467)
13. Social Support/ (40256)
14. Prenatal Care/ (2032)
15. Policy Making/ (26307)
16. Organizational Behavior/ (32497)
17. Personnel Training/ (9994)
18. promotion & maintenance of health & wellness.cc. (68457)
19. motivational interview$.ti,ab,id. (4314)
20. peer counsel$.ti,ab,id. (778)
21. group counsel$.ti,ab,id. (3783)
22. social$ support$.ti,ab,id. (56609)
23. home visit$.ti,ab,id. (4783)
24. ((staff or nurs$ or midwife$ or midwives or doula$ or doctor$ or physician$ or obstetrician$ or p?ediatrician$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,id. (46423)
25. ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth$ or child birth$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,id. (1226)
26. (kangaroo adj3 care).ti,ab,id. (157)
27. baby friendly.ti,ab,id. (122)
28. skin to skin.ti,ab,id. (506)
29. pacifier$.ti,ab,id. (236)
30. ((breast feed$ or breast fed or breastfeed$ or breastfed or lactation) adj on demand).ti,ab,id. (12)
31. rooming in.ti,ab,id. (133)
32. ((hospital$ or health system$ or health care system$) adj3 (policy or policies or initiative$ or program$ or practice$)).ti,ab,id. (6761)
33. or/5-32 (312997)
34. 4 and 33 (1809)
35. ((incr$ or improv$ or support$ or promot$ or encourag$ or counsel$ or educat$ or train$ or teach$ or class$ or facilitat$ or rate or rates) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,id. (2513)
36. ((intervention$ or program$ or clinic or clinics or policy or policies or plan$) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,id. (791)
37. lactation consult$.ti,ab,id. (80)
38. 34 or 35 or 36 or 37 (3429)
39. limit 38 to (english language and yr=“2015 -Current”) (1234)
40. exp randomized controlled trials/ or placebo/ or random sampling/ or experiment controls/ (9051)
41. (randomized or randomised or placebo or randomly or phase iii or phase 3 or controlled trial or RCT or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or randomly or control group).ti,ab. or trial.ti. (285987)
42. 40 or 41 (287299)
43. 38 and 42 (434)

#### PsycInfo via Ovid – bridge 2023

APA PsycInfo <1806 to May Week 2 2023>

1. Breast Feeding/ 4166
2. Lactation/ 1719
3. (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti,ab,id. 8877
4. 1 or 2 or 3 9564
5. Health Promotion/ 28408
6. Counseling/ 25612
7. Counselors/ 9365
8. Motivational Interviewing/ 3025
9. Client Education/ 4576
10. Health Education/ 14765
11. Childbirth Training/ 251
12. Support Groups/ 4612
13. Social Support/ 43290
14. Prenatal Care/ 2225
15. Policy Making/ 29942
16. Organizational Behavior/ 33511
17. Personnel Training/ 10488
18. promotion & maintenance of health & wellness.cc. 73040
19. motivational interview$.ti,ab,id. 4625
20. peer counsel$.ti,ab,id. 797
21. group counsel$.ti,ab,id. 3854
22. social$ support$.ti,ab,id. 60572
23. home visit$.ti,ab,id. 5056
24. ((staff or nurs$ or midwife$ or midwives or doula$ or doctor$ or physician$ or obstetrician$ or p?ediatrician$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,id. 49006
25. ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth$ or child birth$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,id. 1286
26. (kangaroo adj3 care).ti,ab,id. 172
27. baby friendly.ti,ab,id. 126
28. skin to skin.ti,ab,id. 539
29. pacifier$.ti,ab,id. 243
30. ((breast feed$ or breast fed or breastfeed$ or breastfed or lactation) adj on demand).ti,ab,id. 12
31. rooming in.ti,ab,id. 137
32. ((hospital$ or health system$ or health care system$) adj3 (policy or policies or initiative$ or program$ or practice$)).ti,ab,id. 7057
33. or/5-32 332821
34. 4 and 33 1931
35. ((incr$ or improv$ or support$ or promot$ or encourag$ or counsel$ or educat$ or train$ or teach$ or class$ or facilitat$ or rate or rates) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,id. 2659
36. ((intervention$ or program$ or clinic or clinics or policy or policies or plan$) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,id. 830
37. lactation consult$.ti,ab,id. 84
38. 34 or 35 or 36 or 37 3637
39. limit 38 to (english language and yr=“2015 -Current”) 1439
40. exp randomized controlled trials/ or placebo/ or random sampling/ or experiment controls/ 9631
41. (randomized or randomised or placebo or randomly or phase iii or phase 3 or controlled trial or RCT or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or randomly or control group).ti,ab. or trial.ti. 302005
42. 40 or 41 303367
43. 38 and 42 458
44. (202202* or 202203* or 202204* or 202205* or 202206* or 202207* or 202208* or 202209* or 202210* or 202211* or 202212* or 2023*).up. 237959
45. 43 and 44 27

#### PsycInfo via Ovid – bridge 2023

APA PsycInfo <1806 to May Week 4 2024>

1. Breast Feeding/ 4447
2. Lactation/ 1793
3. (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti,ab,id. 9301
4. 1 or 2 or 3 10002
5. Health Promotion/ 29756
6. Counseling/ 26456
7. Counselors/ 9824
8. Motivational Interviewing/ 3204
9. Client Education/ 4795
10. Health Education/ 15368
11. Childbirth Training/ 261
12. Support Groups/ 4778
13. Social Support/ 46122
14. Prenatal Care/ 2406
15. Policy Making/ 33134
16. Organizational Behavior/ 34694
17. Personnel Training/ 10954
18. promotion & maintenance of health & wellness.cc. 78363
19. motivational interview$.ti,ab,id. 4884
20. peer counsel$.ti,ab,id. 814
21. group counsel$.ti,ab,id. 3912
22. social$ support$.ti,ab,id. 64524
23. home visit$.ti,ab,id. 5319
24. ((staff or nurs$ or midwife$ or midwives or doula$ or doctor$ or physician$ or obstetrician$ or p?ediatrician$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,id. 51873
25. ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth$ or child birth$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,id. 1358
26. (kangaroo adj3 care).ti,ab,id. 182
27. baby friendly.ti,ab,id. 131
28. skin to skin.ti,ab,id. 571
29. pacifier$.ti,ab,id. 254
30. ((breast feed$ or breast fed or breastfeed$ or breastfed or lactation) adj on demand).ti,ab,id. 12
31. rooming in.ti,ab,id. 141
32. ((hospital$ or health system$ or health care system$) adj3 (policy or policies or initiative$ or program$ or practice$)).ti,ab,id. 7413
33. or/5-32 353021
34. 4 and 33 2039
35. ((incr$ or improv$ or support$ or promot$ or encourag$ or counsel$ or educat$ or train$ or teach$ or class$ or facilitat$ or rate or rates) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,id. 2819
36. ((intervention$ or program$ or clinic or clinics or policy or policies or plan$) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,id. 877
37. lactation consult$.ti,ab,id. 90
38. 34 or 35 or 36 or 37 3865
39. limit 38 to (english language and yr=“2015 -Current”) 1679
40. exp randomized controlled trials/ or placebo/ or random sampling/ or experiment controls/ 10137
41. (randomized or randomised or placebo or randomly or phase iii or phase 3 or controlled trial or RCT or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or randomly or control group).ti,ab. or trial.ti. 318513
42. 40 or 41 319915
43. 38 and 42 488
44. (202304* or 202305* or 202306* or 202307* or 202308* or 202309* or 20231* or 2024*).up. 229186
45. 43 and 44 33

### Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL) via Wiley

Date Run: 30/03/2022 03:32:27

ID Search Hits
#1 (breastfeed* or breastfed or “breast fed” or lactation):ti,ab,kw 9943
#2 (breast next feed*):ti,ab,kw 5675
#3 (infant or newborn):ti,ab,kw next feeding:ti,ab,kw 1065
#4 #1 or #2 or #3 12007
#5 (motivational next interview*):ti,ab,kw 4589
#6 (peer next counsel*):ti,ab,kw 306
#7 (group next counsel*):ti,ab,kw 809
#8 (social* next support*):ti,ab,kw 9080
#9 (home next visit*):ti,ab,kw 4176
#10 (staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*):ti,ab,kw near/5 (train* or educat* or teach* or class*):ti,ab,kw 15082
#11 (prenatal or “pre natal” or postnatal or “post natal” or atenatal or “ante natal” or childbirth* or (child next birth*)) near/5 (train* or educat* or teach* or class*):ti,ab,kw 969
#12 (kangaroo near/3 care):ti,ab,kw 566
#13 “baby friendly”:ti,ab,kw 103
#14 “skin to skin”:ti,ab,kw 560
#15 pacifier*:ti,ab,kw 318
#16 (breast next feed*):ti,ab,kw near/3 demand:ti,ab,kw 4
#17 (breast fed or breastfeed* or breastfed or lactation):ti,ab,kw near/3 demand:ti,ab,kw 29
#18 “rooming in”:ti,ab,kw 81
#19 (hospital* or “health system” or “health systems” or “health care system” or “health care systems”):ti,ab,kw near/3 (policy or policies or initiative* or program* or practice*):ti,ab,kw 3850
#20 {or #5-#19} 37683
#21 #4 and #20 1547
#22 ((incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat* or rate or rates) near/5 ((breast next feed*) or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)):ti,ab,kw 2707
#23 (intervention* or program* or clinic or clinics or policy or policies or plan*):ti,ab,kw near/5 ((breast next feed*) or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”):ti,ab,kw 1505
#24 (lactation next consult*):ti,ab,kw 130
#25 #21 or #22 or #23 or #24 with Publication Year from 2015 to present, in Trials 2164

#### Cochrane via Wiley – bridge 2023

Date Run: 12/05/2023 18:56:07

ID Search Hits
#1 (breastfeed* or breastfed or “breast fed” or lactation):ti,ab,kw 11017
#2 (breast next feed*):ti,ab,kw 6296
#3 (infant or newborn):ti,ab,kw next feeding:ti,ab,kw 1152
#4 #1 or #2 or #3 13315
#5 (motivational next interview*):ti,ab,kw 5073
#6 (peer next counsel*):ti,ab,kw 326
#7 (group next counsel*):ti,ab,kw 884
#8 (social* next support*):ti,ab,kw 10078
#9 (home next visit*):ti,ab,kw 4576
#10 (staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*):ti,ab,kw near/5 (train* or educat* or teach* or class*):ti,ab,kw 17121
#11 (prenatal or “pre natal” or postnatal or “post natal” or atenatal or “ante natal” or childbirth* or (child next birth*)) near/5 (train* or educat* or teach* or class*):ti,ab,kw 1108
#12 (kangaroo near/3 care):ti,ab,kw 664
#13 “baby friendly”:ti,ab,kw 107
#14 “skin to skin”:ti,ab,kw 644
#15 pacifier*:ti,ab,kw 342
#16 (breast next feed*):ti,ab,kw near/3 demand:ti,ab,kw 4
#17 (breast fed or breastfeed* or breastfed or lactation):ti,ab,kw near/3 demand:ti,ab,kw 27
#18 “rooming in”:ti,ab,kw 87
#19 (hospital* or “health system” or “health systems” or “health care system” or “health care systems”):ti,ab,kw near/3 (policy or policies or initiative* or program* or practice*):ti,ab,kw 4153
#20 {or #5-#19} 42036
#21 #4 and #20 1745
#22 ((incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat* or rate or rates) near/5 ((breast next feed*) or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)):ti,ab,kw 3020
#23 (intervention* or program* or clinic or clinics or policy or policies or plan*):ti,ab,kw near/5 ((breast next feed*) or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”):ti,ab,kw 1685
#24 (lactation next consult*):ti,ab,kw 148
#25 #21 or #22 or #23 or #24 with Publication Year from 2015 to present, with Cochrane Library publication date from Feb 2022 to present, in Trials 540
#26 #25 NOT conference:pt 514
#27 #26 NOT (clinicaltrials or trialsearch):so 265

#### Cochrane via Wiley – bridge 2024

Date Run: 03/06/2024 20:31:51

ID Search Hits
#1 (breastfeed* or breastfed or “breast fed” or lactation):ti,ab,kw 12084
#2 (breast next feed*):ti,ab,kw 6837
#3 (infant or newborn):ti,ab,kw next feeding:ti,ab,kw 1256
#4 #1 or #2 or #3 14552
#5 (motivational next interview*):ti,ab,kw 5511
#6 (peer next counsel*):ti,ab,kw 349
#7 (group next counsel*):ti,ab,kw 940
#8 (social* next support*):ti,ab,kw 10987
#9 (home next visit*):ti,ab,kw 4823
#10 (staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*):ti,ab,kw near/5 (train* or educat* or teach* or class*):ti,ab,kw 18806
#11 ((prenatal or “pre natal” or postnatal or “post natal” or “ante natal” or childbirth* or (child next birth*)) near/5 (train* or educat* or teach* or class*)):ti,ab,kw 1234
#12 (kangaroo near/3 care):ti,ab,kw 745
#13 “baby friendly”:ti,ab,kw 117
#14 “skin to skin”:ti,ab,kw 712
#15 pacifier*:ti,ab,kw 373
#16 (breast next feed*):ti,ab,kw near/3 demand:ti,ab,kw 4
#17 (breast fed or breastfeed* or breastfed or lactation):ti,ab,kw near/3 demand:ti,ab,kw 29
#18 “rooming in”:ti,ab,kw 99
#19 (hospital* or “health system” or “health systems” or “health care system” or “health care systems”):ti,ab,kw near/3 (policy or policies or initiative* or program* or practice*):ti,ab,kw 4449
#20 {or #5-#19} 45794
#21 #4 and #20 1917
#22 ((incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat* or rate or rates) near/5 ((breast next feed*) or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)):ti,ab,kw 3381
#23 (intervention* or program* or clinic or clinics or policy or policies or plan*):ti,ab,kw near/5 ((breast next feed*) or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”):ti,ab,kw 1850
#24 (lactation next consult*):ti,ab,kw 154
#25 #21 or #22 or #23 or #24 with Publication Year from 2015 to present, with Cochrane Library publication date from Apr 2023 to present, in Trials 530
#26 (antenatal near/5 (train* or educat* or teach* or class*)):ti,ab,kw in Trials 406
#27 #26 NOT #20 190
#28 #4 and #27 40
#29 #25 or #28 564
#30 #29 NOT conference:pt 525
#31 #30 NOT (clinicaltrials or trialsearch):so 240

#### CINAHL via Ebsco

S7 S5 AND S6 Limiters - Published Date: 20150101-; English Language Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 1,643
S6 (MH randomized controlled trials) or (MH double-blind studies) or (MH single-blind studies) or (MH random assignment) or (MH pretest-posttest design) or (MH cluster sample) or (TI (randomised OR randomized)) or (AB (random*)) or (TI (trial)) or (MH (sample size) AND AB (assigned OR allocated OR control)) or (MH (placebos)) or (PT (randomized controlled trial)) or (AB (control W5 group)) or (MH (crossover design) OR MH (comparative studies)) or (AB (cluster W3 RCT)) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 944,865
S5 S3 OR S4 Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 16,127
S4 ( (MH “Breast Feeding Promotion”) OR (MH “Breast Feeding/ED”) ) OR ( (MH “Lactation Consultants”) OR TI “lactation consult*” OR AB “lactation consult*” ) OR ( TI ( ((incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat* or rate or rates) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) OR AB ( ((incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat* or rate or rates) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) ) OR ( TI ( ((intervention* or program* or clinic or clinics or policy or policies or plan*) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) OR AB ( ((intervention* or program* or clinic or clinics or policy or policies or plan*) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) ) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 13,845
S3 S1 AND S2 Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 5,937
S2 ( (MH “Counseling”) OR (MH “Peer Counseling”) OR (MH “Motivational Interviewing”) OR (MH “Counselors”) OR (MH “Nurse Counselors”) OR (MH “Nutritional Counseling”) OR (MH “Health Education”) OR (MH “Patient Education”) OR (MH “Patient Discharge Education”) OR (MH “Prenatal Counseling”) OR (MH “Parenting Education”) OR (MH “Childbirth Education”) OR (MH “Kangaroo Care”) OR (MH “Rooming In”) OR (MH “Program Implementation”) OR (MH “Hospital Programs”) ) OR ( (TI “motivational interview*” OR AB “motivational interview*”) OR (TI “peer counsel*” OR AB “peer counsel*”) OR (TI “group counsel*” OR AB “group counsel*”) OR (TI “social* support*” OR AB “social* support*”) OR (TI “home visit*” OR AB “home visit*”) OR (TI “baby friendly” OR AB “baby friendly”) OR (TI “skin to skin” OR AB “skin to skin”) OR (TI pacifier* OR AB pacifier*) OR (TI “rooming in” OR AB “rooming in”) ) OR ( TI ( (((staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*) N5 (train* or educat* or teach* or class*)) ) OR AB ( (((staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*) N5 (train* or educat* or teach* or class*)) ) ) OR ( TI ( ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth* or “child birth*”) N5 (train* or educat* or teach* or class*)) ) OR AB ( ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth* or “child birth*”) N5 (train* or educat* or teach* or class*)) ) ) OR ( TI (kangaroo N3 care) OR AB (kangaroo N3 care) ) OR ( TI ( ((“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation) N1 “on demand”) ) OR AB ( ((“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation) N1 “on demand”) ) ) OR ( TI ( ((hospital* or “health system” or “health systems” or “health care system” or “health care systems”) N3 (policy or policies or initiative* or program* or practice*)) ) OR AB ( ((hospital* or “health system” or “health systems” or “health care system” or “health care systems”) N3 (policy or policies or initiative* or program* or practice*)) ) ) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 342,580
S1 ( (MH “Breast Feeding”) OR (MH “Attitude to Breast Feeding”) OR (MH “Breast Feeding Positions”) OR (MH “Latching, Breastfeeding”) OR (MH “Milk Expression”) ) OR ( TI (breastfeed* OR “breast feed*”) OR AB (breastfeed* OR “breast feed*”) ) OR ( TI (breastfed OR “breast fed”) OR AB (breastfed OR “breast fed”) ) OR ( TI lactation OR AB lactation ) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 37,013

#### CINAHL via Ebsco – bridge 2023

S1 ( (MH “Breast Feeding”) OR (MH “Attitude to Breast Feeding”) OR (MH “Breast Feeding Positions”) OR (MH “Latching, Breastfeeding”) OR (MH “Milk Expression”) ) OR ( TI (breastfeed* OR “breast feed*”) OR AB (breastfeed* OR “breast feed*”) ) OR ( TI (breastfed OR “breast fed”) OR AB (breastfed OR “breast fed”) ) OR ( TI lactation OR AB lactation ) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 38,716
S2 ( (MH “Counseling”) OR (MH “Peer Counseling”) OR (MH “Motivational Interviewing”) OR (MH “Counselors”) OR (MH “Nurse Counselors”) OR (MH “Nutritional Counseling”) OR (MH “Health Education”) OR (MH “Patient Education”) OR (MH “Patient Discharge Education”) OR (MH “Prenatal Counseling”) OR (MH “Parenting Education”) OR (MH “Childbirth Education”) OR (MH “Kangaroo Care”) OR (MH “Rooming In”) OR (MH “Program Implementation”) OR (MH “Hospital Programs”) ) OR ( (TI “motivational interview*” OR AB “motivational interview*”) OR (TI “peer counsel*” OR AB “peer counsel*”) OR (TI “group counsel*” OR AB “group counsel*”) OR (TI “social* support*” OR AB “social* support*”) OR (TI “home visit*” OR AB “home visit*”) OR (TI “baby friendly” OR AB “baby friendly”) OR (TI “skin to skin” OR AB “skin to skin”) OR (TI pacifier* OR AB pacifier*) OR (TI “rooming in” OR AB “rooming in”) ) OR ( TI ( (((staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*) N5 (train* or educat* or teach* or class*)) ) OR AB ( (((staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*) N5 (train* or educat* or teach* or class*)) ) ) OR ( TI ( ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth* or “child birth*”) N5 (train* or educat* or teach* or class*)) ) OR AB ( ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth* or “child birth*”) N5 (train* or educat* or teach* or class*)) ) ) OR ( TI (kangaroo N3 care) OR AB (kangaroo N3 care) ) OR ( TI ( ((“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation) N1 “on demand”) ) OR AB ( ((“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation) N1 “on demand”) ) ) OR ( TI ( ((hospital* or “health system” or “health systems” or “health care system” or “health care systems”) N3 (policy or policies or initiative* or program* or practice*)) ) OR AB ( ((hospital* or “health system” or “health systems” or “health care system” or “health care systems”) N3 (policy or policies or initiative* or program* or practice*)) ) ) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 355,627
S3 S1 AND S2 Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 6,250
S4 ( (MH “Breast Feeding Promotion”) OR (MH “Breast Feeding/ED”) ) OR ( (MH “Lactation Consultants”) OR TI “lactation consult*” OR AB “lactation consult*” ) OR ( TI ( ((incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat* or rate or rates) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) OR AB ( ((incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat* or rate or rates) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) ) OR ( TI ( ((intervention* or program* or clinic or clinics or policy or policies or plan*) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) OR AB ( ((intervention* or program* or clinic or clinics or policy or policies or plan*) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) ) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 14,640
S5 S3 OR S4 Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 16,998
S6 (MH randomized controlled trials) or (MH double-blind studies) or (MH single-blind studies) or (MH random assignment) or (MH pretest-posttest design) or (MH cluster sample) or (TI (randomised OR randomized)) or (AB (random*)) or (TI (trial)) or (MH (sample size) AND AB (assigned OR allocated OR control)) or (MH (placebos)) or (PT (randomized controlled trial)) or (AB (control W5 group)) or (MH (crossover design) OR MH (comparative studies)) or (AB (cluster W3 RCT)) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 1,001,645
S7 S5 AND S6 Limiters - Published Date: 20210201-; English Language
  Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 514

#### CINAHL via Ebsco – bridge 2024

S1 ( (MH “Breast Feeding”) OR (MH “Attitude to Breast Feeding”) OR (MH “Breast Feeding Positions”) OR (MH “Latching, Breastfeeding”) OR (MH “Milk Expression”) ) OR ( TI (breastfeed* OR “breast feed*”) OR AB (breastfeed* OR “breast feed*”) ) OR ( TI (breastfed OR “breast fed”) OR AB (breastfed OR “breast fed”) ) OR ( TI lactation OR AB lactation ) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 39,926
S2 ( (MH “Counseling”) OR (MH “Peer Counseling”) OR (MH “Motivational Interviewing”) OR (MH “Counselors”) OR (MH “Nurse Counselors”) OR (MH “Nutritional Counseling”) OR (MH “Health Education”) OR (MH “Patient Education”) OR (MH “Patient Discharge Education”) OR (MH “Prenatal Counseling”) OR (MH “Parenting Education”) OR (MH “Childbirth Education”) OR (MH “Kangaroo Care”) OR (MH “Rooming In”) OR (MH “Program Implementation”) OR (MH “Hospital Programs”) ) OR ( (TI “motivational interview*” OR AB “motivational interview*”) OR (TI “peer counsel*” OR AB “peer counsel*”) OR (TI “group counsel*” OR AB “group counsel*”) OR (TI “social* support*” OR AB “social* support*”) OR (TI “home visit*” OR AB “home visit*”) OR (TI “baby friendly” OR AB “baby friendly”) OR (TI “skin to skin” OR AB “skin to skin”) OR (TI pacifier* OR AB pacifier*) OR (TI “rooming in” OR AB “rooming in”) ) OR ( TI ( (((staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*) N5 (train* or educat* or teach* or class*)) ) OR AB ( (((staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*) N5 (train* or educat* or teach* or class*)) ) ) OR ( TI ( ((prenatal or pre natal or postnatal or post natal or ante natal or childbirth* or “child birth*”) N5 (train* or educat* or teach* or class*)) ) OR AB ( ((prenatal or pre natal or postnatal or post natal or ante natal or childbirth* or “child birth*”) N5 (train* or educat* or teach* or class*)) ) ) OR ( TI (kangaroo N3 care) OR AB (kangaroo N3 care) ) OR ( TI ( ((“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation) N1 “on demand”) ) OR AB ( ((“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation) N1 “on demand”) ) ) OR ( TI ( ((hospital* or “health system” or “health systems” or “health care system” or “health care systems”) N3 (policy or policies or initiative* or program* or practice*)) ) OR AB ( ((hospital* or “health system” or “health systems” or “health care system” or “health care systems”) N3 (policy or policies or initiative* or program* or practice*)) ) ) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 364,613
S3 S1 AND S2 Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 6,418
S4 ( (MH “Breast Feeding Promotion”) OR (MH “Breast Feeding/ED”) ) OR ( (MH “Lactation Consultants”) OR TI “lactation consult*” OR AB “lactation consult*” ) OR ( TI ( ((incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat* or rate or rates) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) OR AB ( ((incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat* or rate or rates) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) ) OR ( TI ( ((intervention* or program* or clinic or clinics or policy or policies or plan*) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) OR AB ( ((intervention* or program* or clinic or clinics or policy or policies or plan*) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) ) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 15,093
S5 S3 OR S4 Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 17,532
S6 (MH randomized controlled trials) or (MH double-blind studies) or (MH single-blind studies) or (MH random assignment) or (MH pretest-posttest design) or (MH cluster sample) or (TI (randomised OR randomized)) or (AB (random*)) or (TI (trial)) or (MH (sample size) AND AB (assigned OR allocated OR control)) or (MH (placebos)) or (PT (randomized controlled trial)) or (AB (control W5 group)) or (MH (crossover design) OR MH (comparative studies)) or (AB (cluster W3 RCT)) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 1,047,239
S7 S5 AND S6 Limiters - Publication Date: 20230401-; English Language Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 204
S8 TI ( (antenatal N5 (train* or educat* or teach* or class*)) ) OR AB ( (antenatal N5 (train* or educat* or teach* or class*)) ) Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 1,401
S9 S8 NOT S2 Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 688
S10 S1 AND S6 AND S9 Limiters - English Language Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 20
S11 S7 OR S10 Expanders - Apply equivalent subjects
  Search modes - Boolean/Phrase Interface - EBSCOhost Research Databases
  Search Screen - Advanced Search
  Database - CINAHL with Full Text 221

Appendix A Table 1 Study Selection Criteria

Category | Included | Excluded
Population | Adolescents or adults involved with or making decisions about feeding their child | - Parents of preterm or very preterm newborns (<34 weeks of gestation or low or very low birth weight [<2,500 g]), because of their special feeding needs; - Studies limited to special populations of individuals or infants (e.g., persons in institutions, infants with prenatal disease, infants born to substance-exposed individuals, infants in a neonatal intensive care unit, infants born to HIV-positive individuals)
Interventions | Interventions designed to support breastfeeding and the consumption of breastmilk, including individual or group counseling, peer counseling, home visits, structured education, technology- or computer-based support, distribution of written materials, and support provided prenatally, at time of delivery or postpartum | - Healthcare system–level interventions and hospital policies; - Mass media campaigns; - Worksite lactation programs
Comparisons | - Usual care, as defined within each study; - Wait list control; - No attention control | Active breastfeeding support intervention
Outcomes | KQ 1:; - Maternal health outcomes such as rates of breast and ovarian cancer, diabetes mellitus, weight status, or mental health symptoms; - Infant and child health outcomes such as gastrointestinal symptoms, atopic dermatitis, respiratory symptoms, otitis media, asthma, or obesity; KQ 2: Breastfeeding initiation, duration, intensity,^*^ or exclusivity, as defined within each study; KQ 3: Harms associated with breastfeeding intervention (e.g., guilt or anxiety related to infant feeding, severity of postpartum depression, increased incidence of maternal mastitis or nipple pain, newborn hyperbilirubinemia, newborn dehydration, infant failure to thrive)
Setting | Any setting linked with the healthcare system and provision of primary care (e.g., hospital, maternity services, home, or clinic) | - Correctional facilities; - Worksites; - Inpatient/residential facilities
Study design | Randomized, clinical trials^†^ | Non-randomized studies of interventions
Study geography | Studies that primarily take place in countries categorized as “Very High” on the 2019 Human Development Index (as defined by the United Nations Development Programme) | Studies that primarily take place in countries not categorized as “Very High” on the 2019; Human Development Index
Publication language | Studies published in English | Studies published in any language other than English
Quality rating | Fair- or good-quality studies | Poor-quality studies

* Proportion of feedings that are breastmilk.

† Randomization to a breastfeeding support intervention or comparator; can include, but are not limited to: parallel, cluster, pragmatic, factorial, and stepped wedge trial designs as appropriate.

Appendix A Table 2 Quality Rating Criteria for Randomized Clinical Trials

Quality Criteria^*^
Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* Signaling questions from the Cochrane Risk of Bias (RoB 2) tool^1^ along with the design specific criteria from the U.S. Preventive Services Task Force Procedure Manual.^2^