# References

1 Coleman-Jensen A, Rabbitt M, Gregory C, Singh A. Household Food Security in the United States in 2020, ERR-298. 2021. https://www.ers.usda.gov/webdocs/publications/102076/err-298.pdf?v=8916.6
2 Food and Agriculture Organization of the United Nations, International Fund for Agricultural Development, World Food Programme. The State of Food Insecurity in the World. 2015. http://www.fao.org/3/i4646e/i4646e.pdf
3 Loopstra R. Interventions to address household food insecurity in high-income countries. Proc Nutr Soc. 08 2018;77(3):270–281. doi:10.1017/S002966511800006X 29580316
4 United States Department of Agriculture. Definitions of Food Security. United States Department of Agriculture, Economic Research Service. Background. Accessed Sept 21, 2021. https://www.ers.usda.gov/topics/food-nutrition-assistance/food-security-in-the-us/definitions-of-food-security.aspx
5 Gregory C, Coleman-Jensen A. Food Insecurity, Chronic Disease, and Health Among Working-Age Adults, ERR No 235. US Department of Agriculture. Background. https://www.ers.usda.gov/webdocs/publications/84467/err-235.pdf?v=0
6 Radimer KL, Olson CM, Campbell CC. Development of indicators to assess hunger. J Nutr. Nov 1990;120 Suppl 11(suppl_11):1544–8. doi:10.1093/jn/120.suppl_11.1544 2243303
7 Anderson S. Core indicators of nutritional state for difficult-to-sample populations. J Nutr. Nov 1990;120 Suppl 11:1559–600. doi:10.1093/jn/120.suppl_11.1555 2243305
8 Mozaffarian D, Fleischhacker S, Andrés JR. Prioritizing Nutrition Security in the US. JAMA. 2021;325(16):1605–1606. doi:10.1001/jama.2021.1915 33792612
9 United States Department of Agriculture. Food and Nutrition Security. Writing. Accessed Oct 30, 2023. https://www.usda.gov/nutrition-security
10 Association of State Public Health Nutritionists. Food and Nutrition Security Primer-Section Three: Food and Nutrition Security Terms and Definitions. ASPHN. Accessed Sept 4, 2024. https://asphn.org/food-and-nutrition-security-primer-terms/
11 Eder M, Henninger M, Durbin S, . Screening and Interventions for Social Risk Factors: Technical Brief to Support the US Preventive Services Task Force. Jama. Sep 1 2021;326(14):1416–1428. doi:10.1001/jama.2021.12825 34468710
12 Alderwick H, Gottlieb LM. Meanings and Misunderstandings: A Social Determinants of Health Lexicon for Health Care Systems. The Milbank quarterly. Jun 2019;97(2):407–419. doi:10.1111/1468-0009.12390 31069864
13 Green K, Zook M. When talking about social determinants, precision matters. Health Affairs. Background. https://www.healthaffairs.org/do/10.1377/hblog20191025.776011/full/
14 Castrucci B, Auerbach J. Meeting Individual Social Needs Falls Short Of Addressing Social Determinants Of Health. Background. Accessed Nov 10, 2021. https://www.healthaffairs.org/do/10.1377/hblog20190115.234942/full/
15 Billioux A, Verlander K, Anthony S, Alley D. Standardized screening for health-related social needs in clinical settings: The accountable health communities screening tool. Washington, DC: National Academy of Medicine; 2017.
16 Rabbitt MP, Hales LJ, Burke MP, Coleman-Jensen A. Household Food Security in the United States in 2022. 2023. October 2023. Accessed Oct. 30 2023. https://www.ers.usda.gov/webdocs/publications/107703/err-325.pdf?v=6269.8
17 Coleman-Jensen A, Rabbitt M, Gregory C, Singh A. Household Food Security in the United States in 2021. U.S. Department of Agriculture, Economic Research Service; 2022(ERR-309). Background. https://www.ers.usda.gov/webdocs/publications/104656/err-309.pdf?v=9602.3
18 Kim-Mozeleski JE, Pike Moore SN, Trapl ES, Perzynski AT, Tsoh JY, Gunzler DD. Food Insecurity Trajectories in the US During the First Year of the COVID-19 Pandemic. Prev Chronic Dis. Jan 19 2023;20:E03. doi:10.5888/pcd20.220212 36657063
19 Russomanno J, Patterson JG, Jabson JM. Food Insecurity Among Transgender and Gender Nonconforming Individuals in the Southeast United States: A Qualitative Study. Transgend Health. 2019;4(1):89–99. doi:10.1089/trgh.2018.0024 31032424
20 Wilson BD, Conron KJ. National estimates of food insecurity: LGBT people and COVID-19. Los Angeles: UCLA Williams Institute; 2020.
21 Leung CW, Kullgren JT, Malani PN, . Food insecurity is associated with multiple chronic conditions and physical health status among older US adults. Prev Med Rep. Dec 2020;20:101211. doi:10.1016/j.pmedr.2020.101211 32983850
22 Heflin CM, Altman CE, Rodriguez LL. Food insecurity and disability in the United States. Disability and Health Journal. 2019/04/01/ 2019;12(2):220–226. doi:10.1016/j.dhjo.2018.09.006 30322776
23 Coleman-Jensen A. U.S food insecurity and population trends with a focus on adults with disabilities. Physiol Behav. 2020/06/01/ 2020;220:112865. doi:10.1016/j.physbeh.2020.112865 32173340
24 Rabbitt M, Smith M. Food Insecurity Among Working-Age Veterans: A Report summary from the Economic Research Service. Economic Research Service. Background. https://www.ers.usda.gov/webdocs/publications/101269/err-829_summary.pdf?v=7356.9
25 Jernigan VBB, Huyser KR, Valdes J, Simonds VW. Food Insecurity among American Indians and Alaska Natives: A National Profile using the Current Population Survey-Food Security Supplement. J Hunger Environ Nutr. 2017;12(1):1–10. doi:10.1080/19320248.2016.1227750 28491205
26 Odoms-Young A, Bruce MA. Examining the Impact of Structural Racism on Food Insecurity: Implications for Addressing Racial/Ethnic Disparities. Fam Community Health. Apr/Jun 2018;41 Suppl 2 Suppl, Food Insecurity and Obesity(Suppl 2 FOOD INSECURITY AND OBESITY):S3–S6. doi:10.1097/FCH.0000000000000183 29461310
27 Bartfeld J, Dunifon R. State-level predictors of food insecurity among households with children. Journal of Policy Analysis and Management: The Journal of the Association for Public Policy Analysis and Management. 2006;25(4):921–942.
28 Gundersen C. Measuring the extent, depth, and severity of food insecurity: an application to American Indians in the USA. Journal of Population Economics. 2008;21(1):191–215.
29 Kaiser L, Baumrind N, Dumbauld S. Who is food-insecure in California? Findings from the California Women’s Health Survey, 2004. Public Health Nutr. Jun 2007;10(6):574–81. doi:10.1017/s1368980007382542 17381928
30 Stuff JE, Horton JA, Bogle ML, . High prevalence of food insecurity and hunger in households in the rural Lower Mississippi Delta. J Rural Health. Spring 2004;20(2):173–80. doi:10.1111/j.1748-0361.2004.tb00025.x 15085632
31 Yu M, Lombe M, Nebbitt VE. Food stamp program participation, informal supports, household food security and child food security: A comparison of african american and caucasian households in poverty. Children and Youth Services Review. 2010;32(5):767–773.
32 Burke MP, Jones SJ, Frongillo EA, Fram MS, Blake CE, Freedman DA. Severity of household food insecurity and lifetime racial discrimination among African-American households in South Carolina. Ethn Health. Apr 2018;23(3):276–292. doi:10.1080/13557858.2016.1263286 27905205
33 Phojanakong P, Brown Weida E, Grimaldi G, Lê-Scherban F, Chilton M. Experiences of Racial and Ethnic Discrimination Are Associated with Food Insecurity and Poor Health. Int J Environ Res Public Health. Nov 8 2019;16(22)doi:10.3390/ijerph16224369
34 Gundersen C, Ziliak JP. Food Insecurity And Health Outcomes. Health Affairs. 2015/11/01 2015;34(11):1830–1839. doi:10.1377/hlthaff.2015.0645 26526240
35 Kral TVE, Chittams J, Moore RH. Relationship between food insecurity, child weight status, and parent-reported child eating and snacking behaviors. J Spec Pediatr Nurs. Apr 2017;22(2)doi:10.1111/jspn.12177
36 Rose-Jacobs R, Black M, Case P, . Household food insecurity: associations with at-risk infant and toddler development. Pediatrics. 2018;121(1):65–72. doi:10.1542/peds.2006-3717
37 Ryu JH, Bartfeld JS. Household food insecurity during childhood and subsequent health status: the early childhood longitudinal study--kindergarten cohort. Am J Public Health. Nov 2012;102(11):e50–5. doi:10.2105/ajph.2012.300971 22994255
38 Kirkpatrick SI, McIntyre L, Potestio ML. Child hunger and long-term adverse consequences for health. Arch Pediatr Adolesc Med. Aug 2010;164(8):754–62. doi:10.1001/archpediatrics.2010.117 20679167
39 Carter KN, Kruse K, Blakely T, Collings S. The association of food security with psychological distress in New Zealand and any gender differences. Soc Sci Med. May 2011;72(9):1463–71. doi:10.1016/j.socscimed.2011.03.009 21481507
40 Muldoon KA, Duff PK, Fielden S, Anema A. Food insufficiency is associated with psychiatric morbidity in a nationally representative study of mental illness among food insecure Canadians. Soc Psychiatry Psychiatr Epidemiol. May 2013;48(5):795–803. doi:10.1007/s00127-012-0597-3 23064395
41 Vozoris NT, Tarasuk VS. Household food insufficiency is associated with poorer health. J Nutr. Jan 2003;133(1):120–6. doi:10.1093/jn/133.1.120 12514278
42 Heflin CM, Corcoran ME, Siefert KA. Work trajectories, income changes, and food insufficiency in a Michigan welfare population. Social Service Review. 2007;81(1):3–25.
43 Seligman HK, Laraia BA, Kushel MB. Food insecurity is associated with chronic disease among low-income NHANES participants. The Journal of nutrition. 2010;140(2):304–310. doi:10.3945/jn.109.112573 20032485
44 Venci BJ, Lee S-Y. Functional limitation and chronic diseases are associated with food insecurity among U.S. adults. Journal Article. Annals of Epidemiology. 03 2018;28(3):182–188. doi:10.1016/j.annepidem.2018.01.005 29482742
45 Hernandez DC, Reesor LM, Murillo R. Food insecurity and adult overweight/obesity: Gender and race/ethnic disparities. Appetite. Oct 1 2017;117:373–378. doi:10.1016/j.appet.2017.07.010 28739148
46 Wray CM, Tang J, López L, Hoggatt K, Keyhani S. Association of Social Determinants of Health and Their Cumulative Impact on Hospitalization Among a National Sample of Community-Dwelling US Adults. J Gen Intern Med. Aug 5 2021;doi:10.1007/s11606-021-07067-y
47 Heflin CM, Siefert K, Williams DR. Food insufficiency and women’s mental health: findings from a 3-year panel of welfare recipients. Soc Sci Med. Nov 2005;61(9):1971–82. doi:10.1016/j.socscimed.2005.04.014 15927331
48 Huddleston-Casas C, Charnigo R, Simmons LA. Food insecurity and maternal depression in rural, low-income families: a longitudinal investigation. Public Health Nutr. Aug 2009;12(8):1133–40. doi:10.1017/s1368980008003650 18789167
49 Reeder N, Tolar-Peterson T, Bailey RH, Cheng W-H, Evans MW, Jr. Food Insecurity and Depression among US Adults: NHANES 2005-2016. Journal Article. Nutrients. Jul 27 2022;14(15):27. doi:10.3390/nu14153081
50 Pourmotabbed A, Moradi S, Babaei A, . Food insecurity and mental health: a systematic review and meta-analysis. Public Health Nutr. Jul 2020;23(10):1778–1790. doi:10.1017/s136898001900435x 32174292
51 McDougall JA, Anderson J, Adler Jaffe S, . Food Insecurity and Forgone Medical Care Among Cancer Survivors. JCO Oncol Pract. Sep 2020;16(9):e922–e932. doi:10.1200/jop.19.00736 32384017
52 Seligman HK, Jacobs EA, López A, Tschann J, Fernandez A. Food insecurity and glycemic control among low-income patients with type 2 diabetes. Diabetes Care. Feb 2012;35(2):233–8. doi:10.2337/dc11-1627 22210570
53 Reaven GM. Hypothesis: muscle insulin resistance is the (“not-so”) thrifty genotype. Diabetologia. Apr 1998;41(4):482–4. doi:10.1007/s001250050933 9562354
54 Gowda C, Hadley C, Aiello AE. The association between food insecurity and inflammation in the US adult population. Am J Public Health. Aug 2012;102(8):1579–86. doi:10.2105/ajph.2011.300551 22698057
55 Kau AL, Ahern PP, Griffin NW, Goodman AL, Gordon JI. Human nutrition, the gut microbiome and the immune system. Nature. Jun 15 2011;474(7351):327–36. doi:10.1038/nature10213 21677749
56 Nord M. Characteristics of low-income households with very low food security: an analysis of the USDA GPRA food security indicator. 2007. https://www.ers.usda.gov/webdocs/publications/44171/11530_eib25_1_.pdf?v=0
57 Nord M. Food Insecurity in Households with Children: Prevalence, Severity, and Household Characteristics. US Department of Agriculture; 2009.
58 Mateyka P, Yoo J. Share of Income Needed to Pay Rent Increased the Most for Low-Income Households From 2019 to 2021. Suitland, Md: US Census Bureau: Social, Economic, and Housing Statistics Division; 2023.
59 Jackson JA, Branscum A, Tang A, Smit E. Food insecurity and physical functioning limitations among older U.S. adults. Prev Med Rep. Jun 2019;14:100829. doi:10.1016/j.pmedr.2019.100829 30949424
60 Kirby JB, Bernard D, Liang L. The Prevalence of Food Insecurity Is Highest Among Americans for Whom Diet Is Most Critical to Health. Diabetes Care. Jun 2021;44(6):e131–e132. doi:10.2337/dc20-3116 33905342
61 Feeding America. Hunger + Health: Understanding Food Insecurity. Background. Accessed Nov 9, 2021. https://hungerandhealth.feedingamerica.org/understand-food-insecurity/hunger-health-101/
62 Powell LM, Slater S, Mirtcheva D, Bao Y, Chaloupka FJ. Food store availability and neighborhood characteristics in the United States. Prev Med. Mar 2007;44(3):189–95. doi:10.1016/j.ypmed.2006.08.008 16997358
63 Beaulac J, Kristjansson E, Cummins S. A systematic review of food deserts, 1966-2007. Prev Chronic Dis. Jul 2009;6(3):A105.19527577
64 Ver Ploeg M, Breneman V, Farrigan T, . Access to affordable and nutritious food: measuring and understanding food deserts and their consequences: Report to congress. 2009. Accessed Nov. 10, 2021. https://www.ers.usda.gov/publications/pub-details/?pubid=42729
65 Zenk SN, Schulz AJ, Israel BA, James SA, Bao S, Wilson ML. Neighborhood racial composition, neighborhood poverty, and the spatial accessibility of supermarkets in metropolitan Detroit. Am J Public Health. Apr 2005;95(4):660–7. doi:10.2105/ajph.2004.042150 15798127
66 Knight JK, Fritz Z. Doctors have an ethical obligation to ask patients about food insecurity: what is stopping us? J Med Ethics. Jul 14 2021;doi:10.1136/medethics-2021-107409
67 National Research Council. Food Insecurity and Hunger in the United States: An Assessment of the Measure. In: Wunderlich G, Norwood J, editors. Washington, DC: National Academies Press; 2006.
68 De Marchis EH, Torres JM, Benesch T, . Interventions Addressing Food Insecurity in Health Care Settings: A Systematic Review. Ann Fam Med. Sep 2019;17(5):436–447. doi:10.1370/afm.2412 31501207
69 Gattu RK, Paik G, Wang Y, Ray P, Lichenstein R, Black MM. The Hunger Vital Sign Identifies Household Food Insecurity among Children in Emergency Departments and Primary Care. Children (Basel). Oct 2 2019;6(10)doi:10.3390/children6100107
70 Hager ER, Quigg AM, Black MM, . Development and validity of a 2-item screen to identify families at risk for food insecurity. Pediatrics. Jul 2010;126(1):e26–32. doi:10.1542/peds.2009-3146 20595453
71 Makelarski JA, Abramsohn E, Benjamin JH, Du S, Lindau ST. Diagnostic Accuracy of Two Food Insecurity Screeners Recommended for Use in Health Care Settings. Am J Public Health. Nov 2017;107(11):1812–1817. doi:10.2105/ajph.2017.304033 28933929
72 RTI International. Accountable Health Communities (AHC) Model Evaluation: First Evaluation Report. 2020. December
73 Sandhu S, Xu J, Eisenson H, Prvu Bettger J. Workforce Models to Screen for and Address Patients’ Unmet Social Needs in the Clinic Setting: A Scoping Review. Research Support, Non-U.S. Gov’t Review. J. Jan–Dec 2021;12doi:10.1177/21501327211021021
74 Macias-Konstantopoulos W, Ciccolo G, Muzikansky A, Samuels-Kalow M. A pilot mixed-methods randomized controlled trial of verbal versus electronic screening for adverse social determinants of health. Journal Article. J Am Coll Emerg Physicians Open. Feb 2022;3(1):e12678. doi:10.1002/emp2.12678 35224551
75 Careyva BA, Hamadani R, Friel T, Coyne CA. A Social Needs Assessment Tool for an Urban Latino Population. Journal Article Research Support, Non-U.S. Gov’t. J Community Health. 02 2018;43(1):137–145. doi:10.1007/s10900-017-0396-6 28707180
76 Oldfield BJ, Casey M, DeCew A, Morales SI, Olson DP. Screening for Social Determinants of Health Among Children: Patients’ Preferences for Receiving Information to Meet Social Needs and a Comparison of Screening Instruments. Population Health Management. 2021;24(1):141–148. doi:10.1089/pop.2019.0211 32096695
77 Lax Y, Keller K, Silver M, Safadi BM, Hwang EK, Avner JR. The Use of Telemedicine for Screening and Addressing Social Needs in a Primary Care Pediatric Population in Brooklyn, New York. J Community Health. Jul 05 2023;05:05. doi:10.1007/s10900-023-01254-0
78 Moen M, Storr C, German D, Friedmann E, Johantgen M. A Review of Tools to Screen for Social Determinants of Health in the United States: A Practice Brief. Research Support, N.I.H., Extramural. Population Health Management. 12 2020;23(6):422–429. doi:10.1089/pop.2019.0158 31910355
79 Cavaliere B, Martin K, Smith M, Hake M. Key Drivers to Improve Food Security and Health Outcomes: An Evidence Review of Food Bank - Health Care Partnerships and Related Interventions. Connecticut Food Bank, FoodShare, Feeding America. Background. https://hungerandhealth.feedingamerica.org/resource/food-bank-health-care-partnerships-evidence-review/
80 Oronce CIA, Miake-Lye IM, Begashaw MM, Booth M, Shrank WH, Shekelle PG. Interventions to Address Food Insecurity Among Adults in Canada and the US: A Systematic Review and Meta-analysis. JAMA Health Forum. 2021;2(8):e212001. doi:10.1001/jamahealthforum.2021.2001 35977189
81 American Academy of Family Physicians. Social Determinants of Health: guide to social needs screening. https://www.aafp.org/dam/AAFP/documents/patient_care/everyone_project/hops19-physician-guide-sdoh.pdf2019.
82 Pooler J, Levin M, Hoffman V, Karva F, Lewin-Zwerdling A. Implementing Food Security Screening and Referral for Older Patients in Primary Care: A Resource Guide and Toolkit. AARP Foundation and IMPAQ International. Background. http://www.advancingstates.org/sites/nasuad/files/FINAL%20Resource%20Guide%20HI%20Res_0.pdf
83 Holben DH, Marshall MB. Position of the Academy of Nutrition and Dietetics: Food Insecurity in the United States. J Acad Nutr Diet. Dec 2017;117(12):1991–2002. doi:10.1016/j.jand.2017.09.027 29173349
84 Council on Community Pediatrics and Committee on Nutrition. Promoting Food Security for All Children. Pediatrics. 2015;136(5):e1431–e1438. doi:10.1542/peds.2015-3301 26498462
85 American Diabetes Association. Improving Care and Promoting Health in Populations: Standards of Medical Care in Diabetes-2021. Diabetes Care. Jan 2021;44(Suppl 1):S7–s14. doi:10.2337/dc21-S001 33298412
86 Arnett DK, Blumenthal RS, Albert MA, . 2019 ACC/AHA Guideline on the Primary Prevention of Cardiovascular Disease: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. J Am Coll Cardiol. Sep 10 2019;74(10):e177–e232. doi:10.1016/j.jacc.2019.03.010 30894318
87 Serchen J, Atiq O, Hilden D. Strengthening Food and Nutrition Security to Promote Public Health in the United States: A Position Paper From the American College of Physicians. Annals of Internal Medicine. 2022;175(8):1170–1171. doi:10.7326/m22-0390 35759767
88 Committee on Health Care for Underserved Women. Importance of social determinants of health and cultural awareness in the delivery of reproductive health care (ACOG Committee Opinion No 729). Obstetrics & Gynecology. 2018;131(1):e43–e48.29266079
89 Community Preventive Services Task Force. Social Determinants of Health: Fruit and Vegetable Incentive Programs. Accessed Aug 12, 2024. https://www.thecommunityguide.org/media/2024/pdf/sdoh-fruit-vegetable-initiative-programs-508.pdf
90 De Marchis E, Brown E, Aceves B, . State of the Science of Screening in Healthcare Settings. 2022. https://sirenetwork.ucsf.edu/tools-resources/resources/screen-report-state-science-social-screening-healthcare-settings
91 McLeod MR, Vasudevan A, Warnick S, Jr., Wolfson JA. Screening for Food Insecurity in the Primary Care Setting: Type of Visit Matters. J Gen Intern Med. Jan 19 2021:1–3. doi:10.1007/s11606-020-06474-x
92 Going C, Utech A. Food insecurity screenings connect Veterans, resources. Background. Accessed January 13, 2022, https://blogs.va.gov/VAntage/94006/food-insecurity-screenings-connect-veterans-resources/
93 Cohen AJ, Rudolph JL, Thomas KS, . Food Insecurity Among Veterans: Resources to Screen and Intervene. Fed Pract. Jan 2020;37(1):16–23.32047351
94 National Committee for Quality Assurance. HEDIS MY 2024 Measures and Descriptors. NCQA. Accessed March 25, 2024. https://www.ncqa.org/wp-content/uploads/HEDIS-MY-2024-Measure-Description.pdf
95 Centers for Medicare & Medicaid Services Quality Payment Program. Quality ID #487: Screening for Social Drivers of Health Accessed Mar 25, 2024. https://qpp.cms.gov/docs/QPP_quality_measure_specifications/CQM-Measures/2023_Measure_487_MIPSCQM.pdf
96 Institute of Medicine. Capturing Social & Behavioral Domains & Measures in Electronic Health Records: Phase 2. The National Academies Press; 2015. Accessed 2015 Jan 8. https://www.ncbi.nlm.nih.gov/books/NBK268995/
97 Hanson E, Albert-Rozenberg D, Garfield KM, . The evolution and scope of Medicaid Section 1115 demonstrations to address nutrition: a US survey. Health Aff Sch. Feb 2024;2(2)doi:10.1093/haschl/qxae013
98 KFF. Medicaid Waiver Tracker: Approved and Pending Section 1115 Waivers by State. KFF. Background. Updated Jun 5. Accessed Jun 22, 2023. https://www.kff.org/medicaid/issue-brief/medicaid-waiver-tracker-approved-and-pending-section-1115-waivers-by-state/
99 De Marchis EH, Torres JM, Fichtenberg C, Gottlieb LM. Identifying Food Insecurity in Health Care Settings: A Systematic Scoping Review of the Evidence. Fam Community Health. Jan/Mar 2019;42(1):20–29. doi:10.1097/FCH.0000000000000208 30431466
100 Viswanathan M, Kennedy S, Eder M, . Social Needs Interventions to Improve Health Outcomes: Review and Evidence Map. Patient-Centered Outcomes Research Institute; 2021. https://www.pcori.org/sites/default/files/PCORI-Social-Needs-Interventions-to-Improve-Health-Outcomes-Scoping-Review-Evidence-Map-Report.pdf
101 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. 2021. https://www.uspreventiveservicestaskforce.org/uspstf/sites/default/files/inline-files/procedure-manual-2023.pdf
102 Poblacion A, Ettinger de Cuba S, Frank DA, . Development and Validation of an Abbreviated Child and Adult Food Security Scale for Use in Clinical and Research Settings in the United States. J Acad Nutr Diet. Oct 2023;123(10s):S89–S102.e4. doi:10.1016/j.jand.2023.02.004 37730309
103 US Department of Agriculture Economic Research Service. Food Security in the US: Survey Tools. Background. Updated Sept 08, 2021. Accessed Oct 13, 2021. https://www.ers.usda.gov/topics/food-nutrition-assistance/food-security-in-the-u-s/survey-tools/
104 Whiting P, Rutjes A, Westwood M, . QUADAS-2: A Revised Tool for the Quality Assessment of Diagnostic Accuracy Studies. Annals of Internal Medicine. 2011;155(8):529–536. doi:10.7326/0003-4819-155-8-201110180-00009 22007046
105 Higgins J, Savović J, Page M, . Chapter 8: Assessing risk of bias in a randomized trial. In: Higgins J, Thomas J, Chandler J, , eds. Cochrane Handbook for Systematic Reviews of Interventions version 63. 2022.
106 Sterne JA, Hernán MA, McAleenan A, Reeves BC, Higgins JP. Assessing risk of bias in a non-randomized study. In: Higgins J, Thomas J, Chandler J, , eds. Cochrane handbook for systematic reviews of interventions. 2019:621–641.
107 National Heart L, and Blood Institute. Quality assessment tool for studies with no control group. NHLBI. Accessed Aug 28, 2023. https://www.nhlbi.nih.gov/health-topics/study-quality-assessment-tools
108 Berkman ND, Lohr KN, Ansari MT, . Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. Nov 2015;68(11):1312–24. doi:10.1016/j.jclinepi.2014.11.023 25721570
109 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. Dec 22 2004;4(1):38. doi:10.1186/1472-6963-4-38 15615589
110 Lane WG, Dubowitz H, Feigelman S, Poole G. The Effectiveness of Food Insecurity Screening in Pediatric Primary Care. Int J Child Health Nutr. 2014;3(3):130–138. doi:10.6000/1929-4247.2014.03.03.3 28649292
111 Baer TE, Scherer EA, Fleegler EW, Hassan A. Food Insecurity and the Burden of Health-Related Social Problems in an Urban Youth Population. J Adolesc Health. Dec 2015;57(6):601–7. doi:10.1016/j.jadohealth.2015.08.013 26592328
112 Blumberg SJ, Bialostosky K, Hamilton WL, Briefel RR. The effectiveness of a short form of the Household Food Security Scale. Am J Public Health. Aug 1999;89(8):1231–4. doi:10.2105/ajph.89.8.1231 10432912
113 Gundersen C, Engelhard EE, Crumbaugh AS, Seligman HK. Brief assessment of food insecurity accurately identifies high-risk US adults. Journal Article. Public Health Nutr. Jun 2017;20(8):1367–1371. doi:10.1017/S1368980017000180 28215190
114 Harrison C, Goldstein JN, Gbadebo A, Papas M. Validation of a 2-Item Food Insecurity Screen Among Adult General Medicine Outpatients. Journal Article. Population Health Management. 08 2021;24(4):509–514. doi:10.1089/pop.2020.0183 33021444
115 Radandt NE, Corbridge T, Johnson DB, Kim AS, Scott JM, Coldwell SE. Validation of a Two-Item Food Security Screening Tool in a Dental Setting. J Dent Child (Chic). Sep 15 2018;85(3):114–119.30869587
116 Harle CA, Wu W, Vest JR. Accuracy of Electronic Health Record Food Insecurity, Housing Instability, and Financial Strain Screening in Adult Primary Care. Research Support, U.S. Gov’t, P.H.S. JAMA. 02 07 2023;329(5):423–424. doi:10.1001/jama.2022.23631 36749341
117 Berkowitz SA, Delahanty LM, Terranova J, . Medically Tailored Meal Delivery for Diabetes Patients with Food Insecurity: a Randomized Cross-over Trial. J Gen Intern Med. 03 2019;34(3):396–404. doi:10.1007/s11606-018-4716-z 30421335
118 Wu AW, Weston CM, Ibe CA, . The Baltimore Community-Based Organizations Neighborhood Network: Enhancing Capacity Together (CONNECT) Cluster RCT. Research Support, Non-U.S. Gov’t. American journal of preventive medicine. 08 2019;57(2):e31–e41. doi:10.1016/j.amepre.2019.03.013 31248746
119 Morales ME, Epstein MH, Marable DE, Oo SA, Berkowitz SA. Food Insecurity and Cardiovascular Health in Pregnant Women: Results From the Food for Families Program, Chelsea, Massachusetts, 2013-2015. Prev Chronic Dis. Nov 3 2016;13:E152. doi:10.5888/pcd13.160212 27809418
120 Slagel N, Newman T, Sanville L, . Effects of a Fruit and Vegetable Prescription Program With Expanded Education for Low-Income Adults. Journal Article. Health Education & Behavior. May 10 2022;49(5):849–860. doi:10.1177/10901981221091926
121 Aiyer JN, Raber M, Bello RS, . A pilot food prescription program promotes produce intake and decreases food insecurity. Translational Behavioral Medicine. 2019;9(5):922–930. doi:10.1093/tbm/ibz112 31570927
122 Berkowitz SA, Hulberg AC, Placzek H, . Mechanisms Associated with Clinical Improvement in Interventions That Address Health-Related Social Needs: A Mixed-Methods Analysis. Popul Health Manag. Dec 18 2018;doi:10.1089/pop.2018.0162
123 Byker Shanks C, Vanderwood K, Grocke M, . The UnProcessed Pantry Project (UP3): A Community-Based Intervention Aimed to Reduce Ultra-Processed Food Intake Among Food Pantry Clients. Fam Community Health. Jan–Mar 01 2022;45(1):23–33. doi:10.1097/FCH.0000000000000310 34783688
124 Cohen AJ, Richardson CR, Heisler M, . Increasing Use of a Healthy Food Incentive: A Waiting Room Intervention Among Low-Income Patients. American journal of preventive medicine. Feb 2017;52(2):154–162. doi:10.1016/j.amepre.2016.11.008 28109458
125 Cook M, Ward R, Newman T, . Food Security and Clinical Outcomes of the 2017 Georgia Fruit and Vegetable Prescription Program. Journal of Nutrition Education and Behavior. 2021;53(9):770–778. doi:10.1016/j.jneb.2021.06.010 34509277
126 Fischer L, Bodrick N, Mackey ER, . Feasibility of a Home-Delivery Produce Prescription Program to Address Food Insecurity and Diet Quality in Adults and Children. Journal Article. Nutrients. May 10 2022;14(10):10. doi:10.3390/nu14102006
127 Freedman DA, Choi SK, Hurley T, Anadu E, Hebert JR. A farmers’ market at a federally qualified health center improves fruit and vegetable intake among low-income diabetics. Prev Med. 2013;56(5):288–92. doi:10.1016/j.ypmed.2013.01.018 23384473
128 Gottlieb L, Hessler D, Long D, . Are acute care settings amenable to addressing patient social needs: A sub-group analysis. The American journal of emergency medicine. Nov 2018;36(11):2108–2109. doi:10.1016/j.ajem.2018.03.034 29576258
129 Gottlieb LM, Adler NE, Wing H, . Effects of In-Person Assistance vs Personalized Written Resources About Social Services on Household Social Risks and Child and Caregiver Health. JAMA netw. 2020;3(3):e200701. doi:10.1001/jamanetworkopen.2020.0701
130 Izumi BT, Martin A, Garvin T, . CSA Partnerships for Health: outcome evaluation results from a subsidized community-supported agriculture program to connect safety-net clinic patients with farms to improve dietary behaviors, food security, and overall health. Research Support, Non-U.S. Gov’t. Translational Behavioral Medicine. 12 31 2020;10(6):1277–1285. doi:10.1093/tbm/ibaa041 33421087
131 Jones LJ, VanWassenhove-Paetzold J, Thomas K, . Impact of a Fruit and Vegetable Prescription Program on Health Outcomes and Behaviors in Young Navajo Children. Current Developments in Nutrition. 2020;4(8)doi:10.1093/cdn/nzaa109
132 Orsega-Smith E S N, Cotugna N. . Local pediatricians partner with food bank to provide produce prescription program. J Hunger Environ Nutr. 2020;15(3):353–359. doi:10.1080/19320248.2019.1592051
133 Saxe-Custack A, LaChance J, Hanna-Attisha M. Child Consumption of Whole Fruit and Fruit Juice Following Six Months of Exposure to a Pediatric Fruit and Vegetable Prescription Program. Journal Article. Nutrients. Dec 20 2019;12(1):20. doi:10.3390/nu12010025 31861789
134 Scher K, Sohaki A, Tang A, Plum A, Taylor M, Joseph C. A community partnership to evaluate the feasibility of addressing food insecurity among adult patients in an urban healthcare system. Pilot Feasibility Stud. 2022;8(1):59. doi:10.1186/s40814-022-01013-3 35264239
135 Seligman HK, Lyles C, Marshall MB, . A pilot food bank intervention featuring diabetes-appropriate food improved glycemic control among clients in three states. Health affairs (Project Hope). Nov 2015;34(11):1956–63. doi:10.1377/hlthaff.2015.0641 26526255
136 Shankar KN, Dugas JN, Flacks J, . High touch, high trust: Using community health advocates and lawyers to address ED high utilizers. Journal Article. American Journal of Emergency Medicine. Oct 2022;60:171–176. doi:10.1016/j.ajem.2022.07.049 36037733
137 Singer C, Porta C. Improving patient well-being in the United States through care coordination interventions informed by social determinants of health. Journal Article. Health Soc Care Community. Mar 17 2022;17:17. doi:10.1111/hsc.13776
138 Wetherill MS, Chancellor McIntosh H, Beachy C, Shadid O. Design and Implementation of a Clinic-Based Food Pharmacy for Food Insecure, Uninsured Patients to Support Chronic Disease Self-Management. J Nutr Educ Behav. Oct 2018;50(9):947–949. doi:10.1016/j.jneb.2018.05.014 30064811
139 Xie J, Price A, Curran N, Østbye T. The impact of a produce prescription programme on healthy food purchasing and diabetes-related health outcomes. Public Health Nutr. 2021/04/28 ed2021. p. 3945–3955.33902771
140 Kempainen S, Cutts DB, Robinson-O’Brien R, De Kesel Lofthus A, Gilbertson DT, Mino R. A Collaborative Pilot to Support Patients With Diabetes Through Tailored Food Box Home Delivery. Health Promot Pract. Jan 10 2023:15248399221100792. doi:10.1177/15248399221100792
141 Ranjit N, Aiyer JN, Toups JD, . Clinical outcomes of a large-scale, partnership-based regional food prescription program: results of a quasi-experimental study. BMC Res Notes. Feb 10 2023;16(1):13. doi:10.1186/s13104-023-06280-8 36765390
142 Woo Baidal JA, Duong N, Goldsmith J, . Association of a primary care-based mobile food pantry with child body mass index: A propensity score matched cohort study. Pediatric Obesity. 06 2023;18(6):e13023. doi:10.1111/ijpo.13023 36939408
143 Renaud J, McClellan SR, DePriest K, . Addressing Health-Related Social Needs Via Community Resources: Lessons From Accountable Health Communities. Health affairs (Project Hope). 2023 05 17 ed2023. p. 832–840.37196207
144 Rivera RL, Adams M, Dawkins E, . Delivering Food Resources and Kitchen Skills (FoRKS) to Adults with Food Insecurity and Hypertension: A Pilot Study. Nutrients. Mar 17 2023;15(6):17. doi:10.3390/nu15061452
145 Hager K, Du M, Li Z, . Impact of Produce Prescriptions on Diet, Food Security, and Cardiometabolic Health Outcomes: A Multisite Evaluation of 9 Produce Prescription Programs in the United States. Circ Cardiovasc Qual Outcomes. Sep 2023;16(9):e009520. doi:10.1161/circoutcomes.122.009520 37641928
146 Basu S, Berkowitz SA, Davis C, Drake C, Phillips RL, Landon BE. Estimated Costs of Intervening in Health-Related Social Needs Detected in Primary Care. JAMA internal medicine. 2023;doi:10.1001/jamainternmed.2023.1964
147 The White House. Biden-Harris Adminsitration National Strategy on Hunger, Nutrition, and Health. 2022. https://www.whitehouse.gov/wp-content/uploads/2022/09/White-House-National-Strategy-on-Hunger-Nutrition-and-Health-FINAL.pdf
148 Garg A, LeBlanc A, Raphael JL. Inadequacy of Current Screening Measures for Health-Related Social Needs. JAMA. 2023;doi:doi:10.1001/jama.2023.13948
149 Schleifer D, Diep A, Grisham K. It’s about trust: parents’ perspectives on pediatricians screening for social needs. United Hospital Fund. Accessed Jan 1, 2024. https://uhfnyc.org/publications/publication/its-about-trust-SDH/
150 Albert SM, McCracken P, Bui T, . Do patients want clinicians to ask about social needs and include this information in their medical record? BMC Health Serv Res. Oct 22 2022;22(1):1275. doi:10.1186/s12913-022-08652-5 36273141
151 Thomas MK, Amstutz C, Orr-Roderick D, Horter J, Holben DH. Medical Mistrust Among Food Insecure Individuals in Appalachia. Fam Community Health. Jul–Sep 01 2023;46(3):192–202. doi:10.1097/FCH.0000000000000362 37079541
152 Ettinger de Cuba S, Chilton M, Bovell-Ammon A, . Loss Of SNAP Is Associated With Food Insecurity And Poor Health In Working Families With Young Children. Health affairs (Project Hope). May 2019;38(5):765–773. doi:10.1377/hlthaff.2018.05265 31059367
153 Selvaraj K, Korpics J, Osta AD, Hirshfield LE, Crowley-Matoka M, Bayldon BW. Parent Perspectives on Adverse Childhood Experiences & Unmet Social Needs Screening in the Medical Home: A Qualitative Study. Journal Article. Acad Pediatr. Aug 22 2022;22:22. doi:10.1016/j.acap.2022.08.002
154 Runkle NK, Nelson DA. The Silence of Food Insecurity: Disconnections Between Primary Care and Community Organizations. Journal Article. J. 2021;8(1):31–38. doi:10.17294/2330-0698.1765
155 Hamity C, Jackson A, Peralta L, Bellows J. Perceptions and Experience of Patients, Staff, and Clinicians with Social Needs Assessment. The Permanente journal. 2018;22:18–105. doi:10.7812/tpp/18-105
156 Kangovi S, Mitra N, Grande D, . Patient-centered community health worker intervention to improve posthospital outcomes: a randomized clinical trial. JAMA internal medicine. 2014;174(4):535–43. doi:10.1001/jamainternmed.2013.14327 24515422
157 Real FJ, Beck AF, Spaulding JR, Sucharew H, Klein MD. Impact of a Neighborhood-Based Curriculum on the Helpfulness of Pediatric Residents’ Anticipatory Guidance to Impoverished Families. Matern Child Health J. Nov 2016;20(11):2261–2267.27480423
158 Cohen AJ, Oatmen KE, Heisler M, . Facilitators and Barriers to Supplemental Nutrition Assistance Program Incentive Use: Findings From a Clinic Intervention for Low-Income Patients. Research Support, Non-U.S. Gov’t. American journal of preventive medicine. 04 2019;56(4):571–579. doi:10.1016/j.amepre.2018.11.010 30799161
159 Zack RM, Rodriguez Bronico JV, Babbin M, . Facilitators and Barriers to Patient Attendance at a Free Health Center Produce Market. American journal of preventive medicine. 2022;63(3 Suppl 2):S131–S143. doi:10.1016/j.amepre.2022.03.034 35987525
160 Steeves-Reece AL, Totten AM, Broadwell KD, Richardson DM, Nicolaidis C, Davis MM. Social Needs Resource Connections: A Systematic Review of Barriers, Facilitators, and Evaluation. American journal of preventive medicine. 2022;62(5):e303–e315. doi:10.1016/j.amepre.2021.12.002 35078672
161 Marpadga S, Fernandez A, Leung J, Tang A, Seligman H, Murphy EJ. Challenges and Successes with Food Resource Referrals for Food-Insecure Patients with Diabetes. Perm. 2019;23doi:10.7812/TPP/18-097
162 Schickedanz A, Sharp A, Hu YR, . Impact of Social Needs Navigation on Utilization Among High Utilizers in a Large Integrated Health System: a Quasi-experimental Study. J Gen Intern Med. Nov 2019;34(11):2382–2389. doi:10.1007/s11606-019-05123-2 31228054
163 Frost K, Stafos A, Metcalf AL, . Knowledge and barriers related to food insecurity screening in healthcare settings. Journal Article. Public Health Nurs. 07 2022;39(4):770–777. doi:10.1111/phn.13040 35020212
164 Greenthal E, Jia J, Poblacion A, James T. Patient experiences and provider perspectives on a hospital-based food pantry: a mixed methods evaluation study. Public Health Nutr. 2019;22(17):3261–3269. doi:10.1017/S1368980019002040 31486351
165 Garg A, Butz AM, Dworkin PH, Lewis RA, Thompson RE, Serwint JR. Improving the management of family psychosocial problems at low-income children’s well-child care visits: the WE CARE Project. Pediatrics. Sep 2007;120(3):547–58. doi:10.1542/peds.2007-0398 17766528
166 Klein MD, Kahn RS, Baker RC, Fink EE, Parrish DS, White DC. Training in social determinants of health in primary care: does it change resident behavior? Controlled Clinical Trial. Acad Pediatr. Sep–Oct 2011;11(5):387–93. doi:10.1016/j.acap.2011.04.004 21640683
167 O’Toole TP, Roberts CB, Johnson EE. Screening for Food Insecurity in Six Veterans Administration Clinics for the Homeless, June-December 2015. Prev Chronic Dis. Jan 12 2017;14:E04. doi:10.5888/pcd14.160375 28084988
168 Gonzalez JV, Hartford EA, Moore J, Brown JC. Food Insecurity in a Pediatric Emergency Department and the Feasibility of Universal Screening. The western journal of emergency medicine. 2021;22(6):1295–1300. doi:10.5811/westjem.2021.7.52519 34787554
169 Acquah OO, Honsvall Hoefler AM, Zoller I, Manning LP, Pine DJ, Mitchell RF. Improving Identification of Food-Insecure Patients in an Outpatient Clinic Setting. Journal Article. Primer. 2020;4:3. doi:10.22454/PRiMER.2020.115304 32537603
170 Cohen DJ, Wyte-Lake T, Dorr DA, . Unmet information needs of clinical teams delivering care to complex patients and design strategies to address those needs. J Am Med Inform Assoc. 2020;27(5):690–699. doi:10.1093/jamia/ocaa010 32134456
171 McWhorter JW, Danho MP, LaRue DM, . Barriers and Facilitators of Implementing a Clinic-Integrated Food Prescription Plus Culinary Medicine Program in a Low-Income Food Insecure Population: A Qualitative Study. J Acad Nutr Diet. 2022;122(8):1499–1513. doi:10.1016/j.jand.2021.11.016 34839026
172 Canavan CR, D’Cruze T, Kennedy MA, . Missed opportunities to improve food security for pregnant people: a qualitative study of prenatal care settings in Northern New England during the COVID-19 pandemic. Journal Article. BMC Nutr. Jan 24 2022;8(1):8. doi:10.1186/s40795-022-00499-7 35067225
173 Prado Junior JC, Medronho RdA. Spatial analysis of tuberculosis cure in primary care in Rio de Janeiro, Brazil. BMC Public Health. 2021;21(1):1–15. doi:10.1186/s12889-021-11834-1 33388037
174 Cottrell E, Dambrun K, Cowburn S, . Variation in electronic health record documentation of social determinants of health across a national network of community health centers. American journal of preventive medicine. 2019;57(6):S65–S73.31753281
175 Yaun JA, Rogers LW, Marshall A, McCullers JA, Madubuonwu S. Whole Child Well-Child Visits: Implementing ACEs and SDOH Screenings in Primary Care. Clin Pediatr (Phila). May 1 2022:99228221093279. doi:10.1177/00099228221093279
176 Nederveld AL, Duarte KF, Rice JD, Richie A, Broaddus-Shea ET. IMAGINE: A Trial of Messaging Strategies for Social Needs Screening and Referral. American journal of preventive medicine. 09 2022;63(3 Suppl 2):S164–S172. doi:10.1016/j.amepre.2022.04.025 35987528
177 Ridberg RA, Yaroch AL, Nugent NB, Byker Shanks C, Seligman H. A Case for Using Electronic Health Record Data in the Evaluation of Produce Prescription Programs. J. Jan–Dec 2022;13:21501319221101849. doi:10.1177/21501319221101849
178 De Marchis EH, Aceves B, Razon N, Chang Weir R, Jester M, Gottlieb LM. “Wanting the Best for Our Folks”-A Mixed Methods Analysis of Community Health Center Social Risk Screening Initiatives. J Am Board Fam Med. Oct 11 2023;36(5):817–831. doi:10.3122/jabfm.2023.230099R1 37775320
179 Fitzhugh CD, Pearsall MS, Tully KP, Stuebe AM. Social Determinants of Health in Maternity Care: A Quality Improvement Project for Food Insecurity Screening and Health Care Provider Referral. Health Equity. 2021;5(1):606–611. doi:10.1089/heq.2020.0120 34909527
180 Lindau ST, Makelarski J, Abramsohn E, . CommunityRx: A Population Health Improvement Innovation That Connects Clinics To Communities. Health affairs (Project Hope). Nov 1 2016;35(11):2020–2029. doi:10.1377/hlthaff.2016.0694 27834242
181 Bickel G, Nord M, Price C, Hamilton W, Cook J. Guide to Measuring Household Food Security. United States Department of Agriculture, Food and Nutrition Service; Revised 2000. Background. https://naldc.nal.usda.gov/download/38369/PDF
182 Connell CL, Nord M, Lofton KL, Yadrick K. Food security of older children can be assessed using a standardized survey instrument. J Nutr. Oct 2004;134(10):2566–72. doi:10.1093/jn/134.10.2566 15465749
183 County Health Rankings & Roadmaps. Strategies: Policies and programs that work. Background. Accessed Sept 27, 2021. https://www.countyhealthrankings.org/take-action-to-improve-health/what-works-for-health/strategies?keywords=food+security&sort_by=best_match