# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Justin Mills, MD, MPH, at the Agency for Healthcare Research and Quality; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; the National Heart, Lung, and Blood Institute; Office of Disease Prevention; Office of Research on Women’s Health; and the Eunice Kennedy Shriver National Institute of Child Health and Human Development for providing federal partner review of the draft report; Jennifer S. Lin, MD, for mentoring and project oversight; and Melinda Davies, MAIS, Rachel Thomas, MPH, Leslie Perdue, MPH, Katherine Essick, and Debra Burch for technical and editorial assistance at the Kaiser Permanente Center for Health Research.