# Chapter 4 Discussion

Optimal health is difficult to achieve when there are significant social needs such as food insecurity, and health challenges are further exacerbated by inequities in structural and social determinants of health. A substantial proportion of people who are eligible for federal food-related benefits are not enrolled.^146^ Screening presents an opportunity to identify people who could benefit from programs to improve food security, as noted by the recent Biden-⁠Harris Administration National Strategy on Hunger, Nutrition, and Health, which calls for universal food security screening in healthcare settings and connecting people to the services they need.^147^ Unfortunately, there are important limitations to the literature on the benefits of screening for food insecurity.

## Summary of Evidence

We found insufficient evidence on the impact of screening for food insecurity in healthcare settings (Table 22). One fair-quality study among households with children did not show improved food security 6 months after screening and the provision of information to those who screened positive on how to access federal and local food-related assistance. Given the limited evidence base that screening plus referrals improves food insecurity, the indirect chain of evidence becomes important to examine (i.e., whether there are adequate screening tools and whether interventions can improve food security and other outcomes).

Table 22 Summary of Evidence

Key Question | No. Studies Study Designs (No. Observations) | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
Key Question 1 (Benefits of screening) | 1 RCT (n=789) | No difference in the percent reporting food insecurity after 6 months (intervention group, 29.6%; usual care, 29.8%) | Consistency NA Imprecise | Attrition was fairly high (32% overall) and differential between groups (81% in the intervention group vs. 67% in control group) | Insufficient | Conducted in a US healthcare setting; race and ethnicity not reported; lower educational attainment (only 24% had attended any college)
Key Question 2 (Accuracy of screening tools) | 10 accuracy studies (n=123,886) | Abbreviated screeners had adequate concordance with full instruments. Sensitivity was typically above 95% and specificity above 82% for 2-item screeners embedded in the reference standard or administered within the same larger instrument, as was the case for most studies, and likely overestimates accuracy. The 1-item screener had the lowest accuracy with sensitivity of 0.59 and specificity of 0.87 (95% CIs, not reported), but was also the only instance of the screener being administered independently from the reference standard. | Consistent Precise | Minimal evidence in which the screener is independently administered from the reference standard. | Moderate (adequate for detection) | 8 of 10 studies conducted in or recruited from a US healthcare setting; among studies where race and ethnicity were reported, most studies reported that 50% or more of the participants were Black.
Key Question 3 (Harms of screening) | 0 studies | NA | NA | NA | Insufficient | NA
Key Question 4 (Benefits of interventions) | 29 studies (n=74,292): 1 Randomized crossover trial (n=44), 1 Cluster RCT (n=4,917), 3 NRSIs (n=513), 24 single cohort pre-post studies (n=68,818) | Effect sizes for food security at end of study were very wide-ranging but trended in the direction of benefit of reduced food insecurity over time in all 21 studies reporting this outcome. One study rated as “fair” (vs. “poor”) quality, a randomized crossover trial of meal delivery for people with diabetes, found that 41.9% were food insecure while “on-meals” vs 61.5% while “off-meals” (p=0.05). Consumption of fruits and vegetables generally increased after participating in interventions that provided either free food boxes or vouchers. Other outcomes were sparely reported and rarely showed statistically significant improvements. | Consistent (Food security, fruit and vegetable consumption [for intervention providing free food or vouchers]) Other outcomes: Consistency NA or unclear due to heterogeneity in reporting Imprecise (all outcomes) | 27 of 29 studies rated as “poor” quality for the outcomes of interest to this review, raising serious questions about the validity of the findings. | Food insecurity: Low (benefit); All other outcomes: Insufficient | All studies were in at least in part conducted in or recruited from a US healthcare settings; 30% of the included participants were Black, 18% were Hispanic, and 41% were White, among studies where race and ethnicity were reported; one study was limited to people of the Navajo Nation, but there appeared to be minimal other representation of Native Americans; 16 of the 23 studies gave participants free food or vouchers for food, which is unlikely to be feasible for most healthcare settings.
Key Question 5 (Harms of interventions) | 1 Randomized crossover trial (n=44) | 1 person experienced gastrointestinal distress while “on-meal” | Consistency NA Imprecise | Minimal reporting of harms. | Insufficient | Conducted in a US healthcare setting

Abbreviations: NA=not applicable; NRSI=non-randomized studies of interventions; RCT=randomized controlled trial

We found moderate strength of evidence that 2- and 6-item subsets of a longer 18-item food security assessment instrument had good agreement with the full 18-item questionnaire. This evidence may overestimate the accuracy of brief screeners, however, since all but two of these studies examined agreement based on a single administration of the full questionnaire. We found only one study that administered the screener independently from the reference standard; in this study a single-item screener had sensitivity of 0.59 and specificity of 0.87 (95% CIs, not reported), the lowest accuracy of all included studies.^110^

Because of the methodologic limitations of the studies in this review, it was difficult to ascertain the effectiveness of interventions to improve food security and other important outcomes, leading to low strength of evidence. Most were pre-post studies with only a single measurement at baseline and followup. As a result, we have little confidence that changes in food security were due to the intervention (as opposed to individuals’ independent efforts to obtain food resources, for example, or changes in resources over the course of the month or with seasonal work). Setting aside these limitations, the evidence was generally favorable. One very small, fair-quality randomized crossover study did report lower levels of food insecurity when on-meal versus off-meal (42% vs. 62%),^117^ and most of the poor-quality studies that focused on the provision of food or food vouchers generally found improved food security at followup, although many results were not statistically significant. The evidence was more mixed among studies that provided only application support or referrals, although some findings were favorable. Due to the limitations of the data, we could conclude with only low certainty that interventions can improve food security in the short term (1 year or less), particularly those that provide food or vouchers.

Other outcomes were more sparsely reported. The only outcome with consistent evidence of benefit was fruit and vegetable consumption, which improved in many cases when food or vouchers were provided. This finding is consistent with the CPSTF recommendation for fruit and vegetable incentive programs for households with lower incomes.^89^ There was no clear impact on physiologic outcomes or acute healthcare utilization (e.g., ED visits or inpatient stays), although these outcomes were rarely reported. Given the literature indicating that food insecurity is associated with poorer health, as cited in the Introduction section of this review, it is highly plausible that improved food security could help ease the impact of food insecurity on health, although the specifics of what kind of support is needed for whom and for how long cannot be clearly determined from the existing literature.

We found almost no reporting of harms in the included studies, but there may be a risk of some harms nevertheless.^148,149^ For example, patients may have privacy concerns about sharing sensitive financial information, or feel shamed or stigmatized if screening is not handled in a sensitive manner. Lack of trust or hopelessness may develop if, after screening positive for food insecurity, individuals are not informed about resources. Also, the presence of food insecurity does not necessarily indicate a social need, and patients’ understanding of whether they need assistance must be respected; to ignore a patient’s self-assessment and attempt to persuade them to accept help may be viewed as paternalistic or offensive. Finally, parents and caregivers may have fears about Child Protective Services removing children from a home facing difficulties with basic needs such as food or housing security; other patients may fear that participating in interventions could reveal non-citizen status. Other studies have also indicated trust concerns. One study found that those with greater social needs may be uncomfortable with this information being added to their medical record,^150^ and, at least among adults living in Appalachia, those with higher levels of food insecurity had higher levels of medical mistrust than those with lower levels of food insecurity.^151^ In addition, from a societal perspective, there may be some potential downsides of social needs screening, including medicalization of social needs and deemphasis on upstream societal causes, such as criminal justice, housing, tax, and labor policies. There may also be unintended consequences to patients with social risk interventions. As an example, small or moderate increases in income can lead to SNAP or other benefits being reduced or cut off, resulting in financial strain that affects patients’ ability to pay for housing, utilities, healthcare, or food.^152^ Finally, it is worth noting that even interventions that improve food insecurity may not improve nutrition security.

Our findings are consistent with those of other recently published systematic reviews of screening and intervention for food security.^68,80^ In general, much of the evidence is limited to study designs at higher risk of bias and focused on process outcomes (e.g., receipt of referral) or food insecurity status rather than patient health outcomes. For example, in a 2019 systemic review by De Marchis and colleagues evaluating interventions addressing food insecurity in healthcare settings, 17 of the 23 included studies were rated low or very low quality.^68^ And while studies of referral-based interventions reported moderate increases in food program referrals and resource use, studies of interventions providing food or vouchers reported mixed results for actual change in fruit/vegetable intake, with no impact when results were pooled. Another systematic review by Oronce and colleagues in 2021, which was not limited to interventions conducted in healthcare settings, found that the provision of food and monetary assistance was associated with improved food insecurity measures; however, it was unclear whether these changes translated into better health outcomes.^80^ This review rated the strength of evidence for providing food and monetary assistance as high and moderate, respectively, despite concluding that the study limitations were serious and findings were inconsistent. The strength of evidence was based on the clear logic that providing food and monetary assistance improves food security.

## Implementation and Acceptability

Assessment for food insecurity relies on the identification of individuals or households who lack consistent access to nutritious and culturally appropriate food. Multiple factors at the patient, provider, and healthcare system levels may impact the implementation of food insecurity assessment in healthcare settings (summarized in Table 23).^11^

Table 23 Facilitators and Barriers Related to Assessment and Interventions for Food Insecurity (Contextual Questions 6 and 7)

Type | Level | Facilitators | Barriers
Assessments for Food Insecurity | Patient | - Patient awareness and perception; - Trusting patient-provider relationship; - Assurance of confidentiality | - Stigma or shame; - Limited health literacy; - Fear of consequences
Assessments for Food Insecurity | Provider and staff | - Provider training and education; - Screening tools and protocols; - Supportive environment | - Time constraints; - Competing priorities; - Lack of knowledge; - Real or perceived lack of referral resources
Assessments for Food Insecurity | Healthcare System | - Policy support; - Resource allocation; - Integration of services | - Limited resources; - Fragmented care; - Resistance to change; - Data collection, management, and privacy concerns
Interventions for Food Insecurity | Patient | - Patient awareness and perception; - Motivation and readiness; - Social support | - Stigma and shame; - Lack of knowledge and skills; - Limited resources
Interventions for Food Insecurity | Provider and staff | - Provider training and education; - Screening and referral tools; - Collaborative relationships | - Time constraints; - Lack of knowledge; - Inadequate reimbursement
Interventions for Food Insecurity | Healthcare System | - Policy support; - Integration of services; - Data collection and evaluation | - Limited resources; - Fragmented systems; - Inadequate policies and procedures
Interventions for Food Insecurity | Community | - Collaborative partnerships; - Community engagement; - Access to resources | - Limited resources; - Cultural or language barriers; - Geographic differences

Several studies have reported high levels of patient satisfaction with the assessment of food insecurity in healthcare, with or without a broader social needs assessment.^99^ Patient-level factors that may facilitate assessment of food insecurity include increased patient awareness, trusting relationships with their healthcare providers, and assurances of confidentiality.^153,154^ On the other hand, food insecurity assessment programs may evoke feelings of stigma or shame or fear of consequences, eliciting hesitation about disclosing this information.^11,153^ Further, one study found that those with food insecurity had higher levels of mistrust in medical professionals, suggesting the need for sensitive handling to discussions related to social needs.^151^ Also, patients with limited health literacy or language barriers may struggle to understand the purpose or importance of food insecurity assessments, impeding their participation.^153^ These concerns highlight the importance of involving community members in developing screening programs.

The acceptability of healthcare-related interventions for food insecurity is also well supported.^122,126,136,155–157^ In the studies included in this review, use of food and vouchers was very high, suggesting high engagement with those components. On the other hand, enrollment in federal food assistance programs and use of local services was highly variable (7.5% to 97%). Participation levels were higher when navigators or other staff assisted, as compared with the provision of information only. The broader literature identifies factors that support patient engagement, which include understanding the benefits of interventions for food insecurity,^158^ motivation to improve their food security,^153^ and a supportive network of family, friends, or community members. Work conflicts, physical limitations, transportation challenges, and lack of access to grocery stores and fresh produce can hinder patients’ ability to engage in interventions, however.^158–161^ See Appendix F, Contextual Questions 4 (acceptability), 5 (uptake of services), 6 (screening implementation), and 7 (intervention implementation) for more details.

Several studies have reported that providers believe that social needs, including food insecurity, should be addressed in healthcare,^162–164^ and they have low levels of discomfort doing so.^162,165–167^ Provider-level facilitators for food insecurity screening include adequate training and education, access to screening tools and protocols, and a supportive work environment.^66^ The integration of food security assessments with existing organizational practices, such as use of electronic health records or social work referrals, can enhance implementation.^168–170^ One qualitative study reported that nurses implementing a clinic-integrated food prescription program desired additional training in cultural humility (e.g., better understanding of culturally specific beliefs, values, and customs) and behavioral change theory.^171^ See Appendix F, Contextual Questions 4 (acceptability), 6 (screening implementation), and 7 (intervention implementation) for more details.

At the healthcare system level, policies that recognize the importance of addressing food insecurity and allocate resources for interventions are important to facilitate implementation.^172,173^ Simply implementing a risk screening tool in an electronic health record system is unlikely to lead to widespread adoption.^174^ Sufficient resources, including appropriate staffing (e.g., community health workers, translation services), training, and funding can enable healthcare systems to implement food insecurity assessment more effectively.^172,175,176^ Specifically, some authors have suggested the need to ensure that staff who administer social risk screening display empathy and are sensitive to patient’s lived experience and social needs.^148^ These authors suggest involving community members and social service agencies in co-designing social support programs and supporting partnerships with existing community organizations. Additionally, gathering data on implementation is important to monitor the program, understand gaps in the process, identify unintended consequences, and help ensure equitable delivery of screening and interventions.^177^ Indeed, a study among four community health centers found differences in screening for social risk factors by patient race or ethnicity and preferred language, despite widespread support for the screening voiced in provider surveys.^178^

Mandates for social needs screening related to healthcare quality metrics do not provide resources for their implementation, and funding for screening and intervention programs can be an important barrier for healthcare organizations. In addition to limited organizational resources, health-system-level barriers to optimal implementation commonly include fragmented care, resistance to change, and data management difficulties.^168^ Lack of coordination and communication between healthcare systems and community organizations can impede effective implementation, and resistance to the adoption of new practices or screening tools may arise from entrenched systems and routines within a given healthcare system.^179^ Cultural and linguistic diversity within communities can present healthcare systems with challenges in delivering culturally appropriate interventions and engaging diverse populations.^168^ See Appendix F, Contextual Questions 6 (screening implementation) and 7 (intervention implementation) for more details.

Community-level factors may also have an important impact on the implementation of screening and interventions to address food insecurity. Common community-level barriers may include limited resources, cultural or language barriers, and geographic differences between communities. Communities with limited infrastructure, funding, and resources may struggle to develop and sustain interventions to address food insecurity.^172^ Finally, rural communities may face unique challenges, such as limited access to healthcare, transportation, and food retail options, making it difficult to implement interventions effectively. Healthcare systems could help by advocating for robust local and federal social safety net policies.

## Limitations of Our Approach

To provide the evidence most directly relevant to the mission of the USPSTF, we examined only studies of interventions that were conducted in or recruited from U.S. healthcare settings. Although community-based interventions may help improve food insecurity or other outcomes, issues surrounding privacy, trust, and expected scope of services may differ between communities and healthcare settings. Schools and other settings may provide important points of entry for addressing social needs for families with children but were not explored because they are outside the scope of healthcare systems. In addition, differences in the structure of healthcare and social services in other developed countries limits the applicability of studies conducted outside of the United States. While this approach improved the applicability of the research findings to U.S. primary care settings, there may still be differences in the accuracy of the screening instruments in everyday practice, where visits include a wide range of medical acuity and practical implementation barriers.

Although we specified in the a priori Research Plan that we would consider only studies that were conducted in U.S. healthcare settings for all KQs, we included two studies examining the accuracy of screening tools (KQ2) that were not conducted in U.S. healthcare settings. These were studies using data from the U.S. Census Bureau, including very large samples that are representative of the U.S. population. We felt that instrument accuracy might be less vulnerable to variation across settings than studies in individual healthcare settings and therefore that these studies would add potentially valuable information, given their large size and carefully constructed samples to be broadly representative of the U.S. population.

We did not examine the evidence on the effectiveness of federal programs such as WIC and SNAP, since these are not under the control of healthcare systems. We did include studies of interventions to help facilitate enrollment in these federal programs, however.

Another limitation of our review was that the scope only addressed screening and interventions to ameliorate food insecurity, yet people often experience more than one social risk factor. For interventions addressing food security along with other intervention components (e.g., nutrition counseling, medical management, addressing other social needs), we only included food security outcomes. We could not assume that improvements in outcomes other than food security would be due to the food security component rather than other components, so these outcomes were not included in this review. It is possible that other components affected the food security outcomes, limiting our confidence that the intervention’s food security elements would have the same impact without the co-interventions. On the other hand, we focused on food-related interventions, yet there is evidence that improvement in other social domains improves food insecurity (e.g., rental assistance, Medicaid expansion). However, this was outside the scope of the current review.

Due to the focus of the USPSTF on preventive services rather than disease management, we did not include studies limited to people with significant health conditions, such as cancer, congestive health failure, or renal failure. However, access to healthy meals may have an important impact on their health and quality of life.

We focused on the benefits and harms to the enrolled participants in the studies, although there may have been other parties affected by the interventions, such as family members, healthcare clinicians and staff, social services agencies, and community partners. While we did include information found on acceptability of the interventions to clinicians under Contextual Question 4, benefits and harms to these groups were not included in our review. In addition, looking at social needs more broadly, evidence suggests widespread dissemination of community resources may have benefits even in the absence of screening. For example, participants in a CMS innovation project who received information about community resources near their home were both more confident that they could find resources if needed and were likely to share the information with others in their community, thus spreading the benefits of the intervention into the community.^180^

## Limitations of the Literature and Future Research Needs

The included studies yielded little information on whether interventions to improve food security led to improvements in health, and none of the studies conducted analyses showing whether those who showed greater improvement in food security also showed greater improvements in health. Uncertainty about the assessment windows for food insecurity at baseline and followup further limit the strength of the conclusions from the pre-post studies, which constituted the vast majority of the evidence for interventions.

Despite this, there is strong logic to support screening for and assistance ameliorating food insecurity, both because food is a basic need (and lack of food can be presumed to compromise health), and because knowing that a patient is food insecure has important implications for the delivery of healthcare. Given the high plausibility that insufficient access to healthy food has negative impacts on health, the primary questions may be about the optimal form (food, vouchers, or incentives; application support), intensity (how much food, value of the vouchers or incentives, the number and type of locations that accept the vouchers), and duration of an intervention for a particular family to improve health. While these questions were not the focus of our review, we found a growing but still very limited evidence base aimed at addressing these questions. We found several ongoing RCTs in clinicaltrials.gov, most of which were explicitly comparative effectiveness of active interventions, that may help address these questions in coming years (Appendix G Table 1).

Many people with food insecurity have other social needs as well, and it is impossible to isolate the impact of food-related interventions in the larger context of multiple risk factors. Improving food security may be necessary but insufficient to improve health outcomes in the face of other social risk factors. Unless root social causes such as education, employment, and the availability of affordable housing are addressed, the impact of interventions for food insecurity are by nature limited to the duration of the intervention (i.e., the effect ends when support ends).

As noted in the Introduction, there is a difference between social risk factors (e.g., food insecurity) and social needs (risk factors that patients prioritize as something they would like assistance with). Some have pointed out that a focus on social risk factors rather than social needs may foster paternalistic treatment of those with social risk factors, where clinicians may exert pressure upon patients to address their risk factors rather than respecting the patients’ own understanding of their situation and needs.^148^ These authors note that social needs screening is preferable to social risk screening, and they recommend a shared decision-making approach to addressing social needs once risk factors are identified. They note that this requires “authentic bidirectional conversations, cultural humility, and creation of novel partnerships and sharing of data between health care and social service organizations.” The included studies assessed for social risk factors rarely described how or whether social needs were determined after risk factors were identified. Future studies should carefully develop and describe the shared decision-making process once social risk factors have been identified.

Many of the included studies were reports of pragmatic programs where the primary aim was to deliver the intervention rather than to provide robust research findings. Most studies were rated as poor quality for the outcomes of interest to this review; however, due to the limited evidence base and the fact that this is the first USPSTF review on a social risk factor, we included poor-quality evidence on interventions for food insecurity that would typically not be included in systematic reviews for the USPSTF. Given the strong logic that the provision of food, vouchers, and help accessing relevant resources can mitigate food insecurity (at least for the duration of the intervention), RCT evidence may not be necessary to recommend helping those with food insecurity obtain food. In addition, studies with true control groups, without at least some information about accessing resources, may be difficult to justify among populations with food insecurity.

However, a pre-post design with only a single measurement before and after the intervention is too limited to provide information about the impact of the intervention on patients. At the least, multiple measurements before and after the intervention along with measurement of physiologic and health outcomes would provide much stronger evidence that change was related to the intervention rather than other factors, such as policy changes or the efforts of the individual to obtain needed resources. The pre-post studies do suggest that providing patients facing food insecurity with food and vouchers improves food security, but multiple measurements and longer followup after the intervention has ended would elicit much more valuable information. Even more definitive would be carefully conducted implementation studies in large health systems, perhaps with staged roll-out of food insecurity screening across clinics or practice groups and assessment of physiologic and health outcomes with outcomes assessed multiple times, up to 2 years or longer. Studies such as this may become impossible to complete, however, if screening for food insecurity become the standard of care, as is likely with the introduction of National Committee for Quality Assurance and CMS quality metrics on social risk screening that include food insecurity screening. As healthcare systems implement programs to address food insecurity, it is crucial to publish lessons learned, best practices for implementation, how to address contextual factors, and barriers and facilitators to widespread uptake.

## Conclusions

Brief screening tools likely have sufficient sensitivity to identify people with food insecurity in healthcare settings and interventions to improve food insecurity show promise, especially those that directly provide food or vouchers/subsidies; however, most studies suffered from high risk of bias, limiting firm conclusions.