# Chapter 3 Results

## Description of Included Studies

We identified 39 studies (n=198,762) meeting inclusion criteria for this review, including one examining the benefits of screening for food insecurity (KQ1),^110^ 10 examining the accuracy of screening tools (KQ2),^69–71,110–116^ 29 examining the impact of interventions to reduce food insecurity (KQ4),^117–127^ ^128–145^ and one reported on harms of interventions (KQ5), which was also included for KQ4.^117^ One study was included for both KQs 1 and 2.^110^

## KQ1 Does Identifying Food Insecurity in Healthcare Improve Health Outcomes?

### Summary of Results

One fair-quality RCT (n=789) examined the impact of screening for food insecurity, along with other factors related to child maltreatment, among parents with a child younger than age 6 years (Table 3, Table 4).^110^ Families screening positive for food insecurity were given information on how to access federal and local food-related assistance. This RCT found no difference in the percent reporting food insecurity after 6 months between the intervention group (29.6% with food insecurity) and usual care (29.8%; Table 5).

Table 3 Study Characteristics, Key Question 1

Study (Quality rating) | N | Study design | Population | Setting | Screening | Intervention | Food-related components | Non-food areas addressed | Control
Lane, 2014^110^ (Fair) | 789 | cRCT | Parents of children younger than age 6 years | Primary care | Multiple SDOH | Clinician training on screening for child maltreatment risk factors including food insecurity | Food referrals, Community resource referrals, Application support/coordination | Intimate partner violence, parent depression, substance abuse, stress, and corporal punishment | Usual well-child care

Abbreviations: cRCT=cluster randomized clinical trial; SDOH=social determinants of health

Table 4 Population Characteristics, Key Question 1

Study | Age, Mean (Range) | % Women | % Race/Ethnicity | % Food Insecurity and Assistance | % Other Assistance | Other SES
Lane, 2014^110^ | 25.3 (NR) | 92.8 | Asian: NR; Black: NR; Hispanic/Latino: NR; Native Amer: NR; White: NR; Multiracial: NR | Food Insecurity: 32.0; SNAP: NR; WIC: NR | NR | Education: < HS: 39%, HS or GED: 37%, Some college: 24%; Employed: 32%; Household size, mean (SD): 2.2 (1.2) adults, 2.3 (1.4) children

Abbreviations: GED=general equivalency diploma; HS=high school; NR= not reported; SD=standard deviation; SES=socioeconomic status; SNAP=Supplemental Nutrition Assistance Program; WIC=Supplemental Nutrition Program for Women, Infants, and Children

Table 5 Results, Key Question 1

Study | Outcome | Measure | Group analyzed | Timepoint (months) | IG n/N (%) | CG n/N (%) | Effect (95% CI)
Lane, 2014^110^ | Food insecurity | HFSS-18 | All | 6 | 66/223 (29.6); BL: 32.7% | 48/161 (29.8); BL: 31.1% | RR^*^: 0.99 (0.73 to 1.36)

* Calculated unadjusted RR

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; HFSS=Household Food Security Survey; IG=intervention group; RR=relative risk

### Detailed Results

We identified one study (n=789) that examined the benefits of screening for food insecurity compared with usual care at an urban clinic serving children from low-income families.^110^ This RCT trained pediatric residents assigned to the intervention group to screen parents of children younger than age 6 years for child maltreatment risk factors, including food insecurity, intimate partner violence, parent depression, substance abuse, and use of corporal punishment. Parents who screened positive for food insecurity were given information on how to apply for SNAP benefits and other federal food assistance programs and information about local food resources such as food pantries. Ninety-three percent of study participants were African American, 93 percent were women, and 76 percent had a high school education or less. This study was rated as fair quality (Appendix A Figure 2, Lane, 2014 study). The main methodologic concerns were the relatively high overall attrition rate (32%) and the difference between groups in completing the baseline assessment (81% in the intervention group vs. 67% in the control group), leading to concerns about baseline comparability between groups.

The only reported outcome that met our inclusion criteria was food insecurity, as measured by the 18-item HFSS-18. At the 6-month followup, there was no difference in food insecurity between groups (29.6% in the intervention group [from 32.7% at baseline] vs. 29.8% in the usual care group [from 31.1% at baseline]; p=0.9). This is despite the fact that a larger proportion of the intervention participants had maintained SNAP enrollment at the 6-month followup (97% of intervention participants were still enrolled after 6 months vs. 81% of control participants; p=0.05)

## KQ2 What Is the Performance of Risk Assessment or Screening Tools to Identify Food Insecurity?

### Summary of Results

Ten studies (n=123,886) examined the accuracy of a brief screening instrument to identify individuals or families with food insecurity (Table 6).^69–71,110–116^ These studies examined 1-item, 2-item, or 6-item screeners (Table 7), all derived from the USDA’s HFSS-18.^17^ Sensitivity was typically above 95 percent and specificity above 82 percent for all 2-item screeners when the screener was fully embedded in the reference standard, as was the case for most studies, or administered within the same larger questionnaire (Table 8, Figure 2). The lack of independent administration of the screener is likely to overestimate the performance of the screener under usual clinical use. The 1-item screener had the lowest accuracy, with sensitivity of 0.59 and specificity of 0.87 (95% CIs, not reported), but was also the only instance of the screener being administered independently from the reference standard. ^110^

Table 6 Study Characteristics, Key Question 2

Study (Quality rating) | N | Screener | Ref Standard | Setting (Participant selection) | Population | Mean Age (Range) | Race and ethnicity | Food Insecurity (%) | Assistance (%) | Other SES
Baer, 2015^111^ (Fair) | 400 | HFSS-2 (HVS) | USDA-FSS | Primary care (Convenience) | Adults, Teenagers | Adult: 18 (15-25); Child: NA (NA) | AI or AN: NR; Asian or PI: NR; Black: 55; Hispanic: 29; White: 9 | 32.5 | SNAP: NR; WIC: NR; Public insurance: 59 | Education: In HS: 48%, Did not complete HS: 10%, HS grad or GED: 10%, >HS grad: 32%; Employment status: Student only: 57%, Employed: 25%, Unemployed: 14%, Unable to work: 4%
Blumberg, 1999^112^ (Fair) | 44647 | HFSS-6 | HFSS-18 | Other: 1995 Current Population Survey (US Census Bureau) (NR) | Adults | Adult: NR (NR); Child: NA (NA) | AI or AN: NR; Asian or PI: NR; Black: NR; Hispanic: NR; White: NR | NR | SNAP: NR; WIC: NR | NR
Gattu, 2019^69^ (Fair) | 5039 | HFSS-2 (HVS) | HFSS-18 | Primary care, ED (All eligible) | Families with children | Adult: NR (NR); Child: NR (NR) | AI or AN: NR; Asian or PI: NR; Black: 88.8; Hispanic: NR; White: 6.4 | 21.5 | SNAP: NR; WIC: NR | Maternal education: Some HS or less: 22.5%, HS grad: 77.5%; Maternal employment: 43.0%; Housing insecure: 28.1%
Gundersen, 2017^113^ (Fair) | 42081 | HFSS-2 (HVS); Items 1 & 3; Items 2 & 3 | HFSS-18 | Other: 2013 Current Population Survey (US Census Bureau) (NR) | Adults | Adult: NR (NR); Child: NA (NA) | AI or AN: NR; Asian or PI: NR; Black: NR; Hispanic: NR; White: NR | 14.2 | SNAP: NR; WIC: NR | NR
Hager, 2010^70^ (Fair) | 30098 | HFSS-2 (HVS) | HFSS-18 | Primary care, ED (All eligible) | Families with children | Adult: NR (NR); Child: NR (0-3) | AI or AN: 0.3; Asian or PI: 1.4; Black: 53.6; Hispanic: 30.4; White: 13.6 | 23 | SNAP: NR; WIC: NR | Uninsured or receiving public insurance: 100%
Harle, 2023^116^ (Fair) | 826 | HFSS-2 (HVS) | HFSS-6 | Primary care (NR) | Adults | Adult: 49.7 (NR); Child: NR (NA) | AI or AN: NR; Asian or PI: NR; Black: 39.2; Hispanic: 6.8; White: 44.8 | 36.0 | SNAP: NR; WIC: NR | Education: Less than high school: 6.5%; High school graduate or equivalent: 24.3%; Some postsecondary ed or higher: 66.8%
Harrison, 2021^114^ (Fair) | 295 | HFSS-2 (HVS) | HFSS-18 | Primary care (Convenience) | Adults | Adult: 53 (18-93); Child: NA (NA) | AI or AN: NR; Asian or PI: NR; Black: 50.7; Hispanic: NR; White: 41.8 | 17.6 | SNAP: NR; WIC: NR; Medicaid: 24.8; Medicare: 31.5 | Commercial insurance: 40.2%
Lane, 2014^110^ (Fair) | 205 | HFSS-1 | HFSS-18 | Primary care (Random) | Families with children | Adult: 25.3 (NR); Child: NR (0-6) | AI or AN: NR; Asian or PI: NR; Black: 93.0; Hispanic: NR; White: NR | 32.0 | SNAP: 98.4; WIC: NR | Education: <HS: 38.7%, HS or GED: 37.1%, Some college: 24.2%; Employed: 32.4%
Makelarski, 2017^71^ (Fair) | 154 | HFSS-2 (AAP); HFSS-2 (HVS) | HFSS-6 | ED, Pediatric ED (Convenience) | Adults | Adult: NR (18-73); Child: NA (NA) | AI or AN: NR; Asian or PI: NR; Black: 77; Hispanic: 7; White: 8 | 46 | SNAP: NR; WIC: NR | Maternal education: HS grad: 32%; Maternal employment: 43.0%; Housing insecure: 28.1%
Radandt, 2018^115^ (Fair) | 141 | HFSS-2 (HVS) | HFSS-6 | Dental (Convenience) | Families with children | Adult: NR (NR); Child: NR (NR) | AI or AN: NR; Asian or PI: 11.3; Black: NR; Hispanic: 14.9; White: 63.1 | 31.2 | SNAP: NR; WIC: NR; Medicaid: 66 | Single adult household: 31.9%

Abbreviations: AAP=American Academy of Pediatrics; AI=American Indian; AN=Alaskan Native; ED=emergency department; GED=general equivalency diploma; HFSS=Household Food Security Survey; HS=high school; HVS=Hunger Vital Sign; NA=not applicable; NR= not reported; PI=Pacific Islander; SES=socioeconomic status; SNAP=Supplemental Nutrition Assistance Program; USDA-FSS=US Dept of Agriculture-Food Security Survey; WIC=Supplemental Nutrition Program for Women, Infants, and Children

Table 7 Screening Tools, Key Question 2

Screener | Items | Scoring
HFSS-1 | In the last year, did you worry that your food would run out before you got money or food stamps to buy more? | Response categories: Yes, No; “Yes” was considered a positive screen
HFSS-2 (HVS); HFSS-2 (AAP) | 1. We worried whether our food would run out before we got money to buy more.; 2. The food we bought just didn’t last and we didn’t have money to get more. | Response categories:; Hunger Vital Sign (HVS): Often true, Sometimes true, Never true; American Academy of Pediatrics (AAP): Yes, No; Affirmative response to either item was considered a positive screen.
3 items examined in Gunderson 2017^113^ | 1. We worried whether our food would run out before we got money to buy more.; 2. The food we bought just didn’t last and we didn’t have money to get more.; 3. [I/We] couldn’t afford to eat balanced meals. | Response categories: Often true, Sometimes true, Never true.; Examined all pair combinations of these three items; affirmative response to either item was considered a positive screen.
6-item | 1. In the last 12 months, since (date 12 months ago), did you (or other adults in your household) ever cut the size of your meals or skip meals because there wasn’t enough money for food?; 2. IF YES: How often did this happen-almost every month, some months but not every month, or in only 1 or 2 months?; 3. In the last 12 months, did you ever eat less than you felt you should because there wasn’t enough money to buy food?; 4. In the last 12 months, since (date 12 months ago), were you ever hungry but didn’t eat because you couldn’t afford enough food?; 5. The food that [I/we] bought just didn’t last, and [I/we] didn’t have money to get more. Was that often, sometimes, or never true for you in the last 12 months?; 6. [I/We] couldn’t afford to eat balanced meals. Was that often, sometimes, or never true for you in the last 12 months? | Affirmative response to 2 or more items was considered a positive screen.

Abbreviations: AAP=American Academy of Pediatrics; HFSS=Household Food Security Survey; HVS=Hunger Vital Sign

Table 8 Sensitivity and Specificity of Food Security Screeners, Results From Full Study Samples

Study | Screener | Reference Standard | Independence of screener | Format | Sensitivity (95% CI) | Specificity (95% CI)
Lane, 2014^110^ | HFSS-1 | HFSS-18 | Administered independently | Self-administered (paper-and-pencil) | 0.59 (NR to NR) | 0.87 (NR to NR)
Makelarski, 2017^71^ | HFSS-2 (AAP) | HFSS-6 | Partially embedded | Self-administered (paper-and-pencil) | 0.76 (0.65 to 0.85) | 0.93 (0.85 to 0.97)
Gattu, 2019^69^ | HFSS-2 (HVS) | HFSS-18 | Fully embedded | Interviewer administered | 0.97 (0.96 to 0.98) | 0.86 (0.85 to 0.87)
Gundersen, 2017^113^ | HFSS-2 (HVS) | HFSS-18 | Fully embedded | Interviewer administered | 0.97 (NR to NR) | 0.93 (NR to NR)
Hager, 2010^70^ | HFSS-2 (HVS) | HFSS-18 | Fully embedded | Interviewer administered | 0.97 (0.96 to 0.97) | 0.83 (0.82 to 0.83)
Harrison, 2021^114^ | HFSS-2 (HVS) | HFSS-18 | Fully embedded | Interviewer administered | 0.98 (0.94 to 1) | 0.91 (0.87 to 0.94)
Harle, 2023^116^ | HFSS-2 (HVS) | HFSS-6 | Same larger questionnaire | NR | 0.95 (0.91 to 0.97) | 0.93 (0.91 to 0.95)
Makelarski, 2017^71^ | HFSS-2 (HVS) | HFSS-6 | Partially embedded | Self-administered (paper-and-pencil) | 0.94 (0.86 to 0.98) | 0.82 (0.72 to 0.9)
Radandt, 2018^115^ | HFSS-2 (HVS) | HFSS-6 | Fully embedded | Self-administered (paper-and-pencil) | 0.95 (0.85 to 0.99) | 0.84 (0.75 to 0.9)
Baer, 2015^111^ | HFSS-2 (HVS) | USDA-FSS | Fully embedded | Self-administered (computer-based) | 0.88 (0.82 to 0.93) | 0.84 (0.79 to 0.88)
Blumberg, 1999^112^ | HFSS-6 | HFSS-18 | Fully embedded | Interviewer administered | 0.92 (NR to NR) | 0.99 (NR to NR)
Gundersen, 2017^113^ | Items 1 & 3 | HFSS-18 | Fully embedded | Interviewer administered | 0.99 (NR to NR) | 0.91 (NR to NR)
Gundersen, 2017^113^ | Items 2 & 3 | HFSS-18 | Fully embedded | Interviewer administered | 0.97 (NR to NR) | 0.94 (NR to NR)

Note: Fully embedded: all items in the screener were administered as part of the reference standard, the sensitivity and specificity reflect agreement of the subset of items with the full scale; Partially embedded: one or more items (but not all) were administered as part of the reference standard

Abbreviations: AAP=American Academy of Pediatrics; CI=confidence interval; HFSS=Household Food Security Survey; HVS=Hunger Vital Sign; NR=not reported; USDA-FSS=US Dept of Agriculture-Food Security Survey

Figure 2 Sensitivity and Specificity of Brief Screeners for Food Insecurity, Key Question 2

Figure 2 is a forest plot depicting the sensitivity and specificity of brief screeners for food insecurity compared to a reference standard. Figure 2 is discussed in the Results section.

### Detailed Results

#### Study Characteristics

We included 10 fair-quality studies (n=123,886) that examined the accuracy of a brief screening instrument to identify individuals or families with food insecurity (Table 6).^69–71,110–116^ These studies examined 1-item, 2-item, or 6-item screeners (Table 7), all derived from the HFSS-18.^1^ Most used a standard 2-item screener with the following items referencing the previous 12 months:

- “We worried whether our food would run out before we got money to buy more.”
- “The food we bought just didn’t last and we didn’t have money to get more.”

An affirmative response to either item was considered a positive screen, and studies used either 2- or 3-level response options (2-level: yes or no, as originally recommended by the American Academy of Pediatrics^84^; 3-level: often true, sometimes true, or never true, which we will refer to as the Hunger Vital Sign scoring). One study examined all 2-item combinations of three items: the two items listed above along with a third item “[I/We] couldn’t afford to eat balanced meals.” ^113^ The study examining the single-item screener used a variant of the first item above: “In the last year, did you worry that your food would run out before you got money or food stamps to buy more?”^110^

Six of the studies compared the screening tools with the HFSS-18.^69,70,110,112–114^ Of the remaining studies, three used the 6-item version of the Household Food Security Survey (HFSS-6) as the reference standard,^71,115,116^ and another used the relevant USDA food security survey (USDA-FSS) based on the age and parental status of the respondent (HFSS-18 for adults self-identifying as parents, 10-item Adult Food Security Survey Module for patients age 18 years or older who were not parents, 9-item Self-Administered Food Security Survey Module for Youths for participants ages 15 to 17 years).^111^

In all studies, the reference standard and screening tool were administered on the same day, either via interview^69,70,112–114^ or self-administration^71,110,111,115^ (one study did not report the administration format).^116^

Study settings included primary care,^69,70,110,111,114,116^ emergency department [ED],^69–71^ and dental^115^ settings. We also included two studies that did not have direct ties to healthcare settings but were highly representative of the general U.S. population, being collected as part of the census in 1995^112^ and 2013.^113^

Some studies were limited to families with children,^69,70,110,115^ and another included caregivers from pediatric as well as adult settings to ensure substantial representation of families with children.^71^ One study was limited to adolescents and young adults ages 15 to 25 years,^111^ and the remaining studies recruited adults.^71,112–114,116^ In six^69–71,110,111,114^ of the eight studies that reported on race and ethnicity, more than half of the study samples comprised Black adults. Hispanic participation ranged from 6.8 to 30.4 percent,^70,71,111,114–116^ and White adults comprised 6.4 to 63.1 percent^69–71,111,114–116^ of the samples. Two studies reported the percent of participants who were Asian or Pacific Islander (1.4%^70^ and 11.3%^115^); only one study reported on the percent of participants who were American Indian or Alaska Native (0.3%).^70^

#### Risk of Bias

The main quality-related concern for these studies was that only one study reported separate administration of the screening tool and the reference standard. ^110^ For eight of the nine other studies, one^71^ or both^69,70,111–115^ screening items were part of the reference standard. For these eight studies (which we refer to as having the screener “embedded” in the reference standard), only the reference standard was administered to participants, and subsequent analyses examined how well the subset of the items corresponded to the full instrument.^69,70,111–115^ The final study administered a single larger questionnaire that included the 2-item screener and the 6-item reference standard in different sections of the questionnaire.^116^ Other concerns were that many samples were described as convenience samples, rather than as random or consecutive samples of a known population; some studies provided limited information on how the samples were selected; and some studies provided limited information on how representative their samples were of the target populations.

#### Results

Sensitivity was typically 95 percent or higher and specificity above 82 percent for all 2-item screeners when the screener was fully embedded in the reference standard and when the screener and reference standard were each administered within the same larger questionnaire (Table 8, Figure 2). The lack of independent administration of the screener is likely to overestimate the performance of the screener under usual clinical use. In these studies, sensitivity and specificity were similarly very high in subgroup analyses among participants who were Black or Hispanic; were immigrants; had disabilities; had incomes below 100 percent or 200 percent of the federal poverty limit; had or did not have children in the household; and had adults older than age 60 years in the household (Appendix D Table 1). For one study in which one of the two screening items was embedded in the reference standard and the other was not (but were still administered in a single sitting), sensitivity was lower and specificity was higher when the original American Academy of Pediatrics yes/no response categories was used than when the standard 3-level response was used.^71^ In this study, sensitivity was 0.76 (95% CI, 0.65 to 0.85) and specificity was 0.95 (95% CI, 0.85 to 0.97) with the yes/no scoring method, compared with sensitivity of 0.94 (95% CI, 0.86 to 0.98) and specificity 0.82 (95% CI, 0.72 to 0.9) with the standard 3-level scoring. The 1-item screener had the lowest accuracy, with sensitivity of 0.59 and specificity of 0.87 (95% CIs, not reported).^110^ This study was the only one that administered the screener separately from the reference standard. We detected no pattern of results related to whether the screener was self-administered or administered by an interviewer.

## KQ3 What Are the Harms or Unintended Consequences of Assessment for Food Insecurity?

No studies reported harms or unintended consequences of assessment for food insecurity.

## KQ4 What Is the Effect of Healthcare-Related Interventions to Address Food Insecurity on Food Security, Intermediate Outcomes, or Health Outcomes?

### Summary of Results

Twenty-nine studies (n=74,292) examined interventions to address food insecurity,^117–145^ and all but two^117,142^ were rated as poor quality (Table 10). Six of the studies targeted families with children,^126,128,129,131,133,142^ and the remaining focused on adult populations. Of the two studies rated as fair quality, one was a randomized crossover trial (n=44) that included home delivery of medically tailored meals to patients with diabetes for 12 weeks.^117^ At the end of the 24-week study period, the intervention was associated with reduced food insecurity (41.9% while on-meals vs. 61.5% while off-meals; p=0.05) (Figure 3), improved mental health quality of life (4.7-point change from baseline while on-meals vs. 0.8-point change while off-meals), and improved diet quality (e.g., the 100-point total Healthy Eating Index score improved by 14.1 points while on-meals compared with baseline but declined by 17.3 points while off-meals). However, there was no apparent impact on other quality-of-life measures; physiologic measures of blood pressure, lipid levels, or glucose levels; or cost-related medication underuse. The other study rated as fair quality was an NRSI that compared children in families who participated in a mobile food pantry with a propensity-score matched cohort of pediatric patients from the same neighborhood as the mobile pantry participants, or from nearby neighborhoods not offering a mobile pantry program after 6 months.^142^ This study found a smaller increase in body mass index (BMI) among children of families who participated in the mobile food pantry. This study did not report between-group differences in food insecurity but reported a reduction from 4.3 to 3.3 on a 6-point food insecurity scale among participants in the intervention group.

Table 10 Overview of Studies, All Interventions, Key Question 4

Intervention type; Study | Quality rating^*^ | N | Study design | Population | Identified via screening^†^ | Provides free food | Provides vouchers | Provides application support | Provides referrals
Food security only intervention (FS Only)
Berkowitz, 2019^117^ | Fair | 44 | Randomized crossover trial | Patients with diabetes | Yes | X
Woo Baidal, 2023^142^ | Fair | 176 | NRSI | Families with children age <6 years | Yes | X | | | X
Aiyer, 2019^121^ | Poor | 242 | Pre-post | Adult patients and parents of pediatric patients | Yes | X
Cohen, 2017^124^ | Poor | 177 | Pre-post | SNAP enrolled adults | Yes | | X | | X
Freedman, 2013^127^ | Poor | 45 | Pre-post | FQHC patients with diabetes | No | | X
Izumi, 2020^130^ | Poor | 80 | Pre-post | FQHC patients | No | X
Kempainen, 2023^140^ | Poor | 281 | Pre-post | Adults with type 2 diabetes and food insecurity | Yes | IG1 | | | IG1, IG2
Morales, 2016^119^ | Poor | 290 | NRSI | Pregnant women | Yes | | | X | X
Orsega-Smith, 2020^132^ | Poor | 41 | Pre-post | Adults who are Medicaid enrollees, overweight, or have 2+ children | Yes | X
Ranjit, 2023^141^ | Poor | 2028 | Pre-post | Adults who are food insecure and diagnosed with prediabetes/diabetes, hypertension, or obesity | No | X
Saxe-Custack, 2019^133^ | Poor | 261 | Pre-post | Parents of children ages 7 to 18 years (regardless of food insecurity status) | No | | X
Scher, 2022^134^ | Poor | 340 | Pre-post | Adults | Yes | X
Wetherill, 2018^138^ | Poor | 80 | Pre-post | Uninsured patients attending a chronic disease clinic | No | X
Xie, 2021^139^ | Poor | 353 | Pre-post | Adults with diabetes (subgroup)^‡^ | Yes | | X
Food security intervention with nutrition education (FS + Nutr ed)
Byker Shanks, 2022^123^ | Poor | 43 | Pre-post | Adults at risk for chronic disease | No | X
Cook, 2021^125^ | Poor | 185 | Pre-post | Adults with risk factor for diet-related chronic condition | Yes | | X
Fischer, 2022^126^ | Poor | 25 | Pre-post | Families with young children and diet-related chronic disease risk factor | Yes | X
Hager, 2023^145^ | Poor | 3881 | Pre-post | Adults with, or at risk for, poor cardiometabolic health | No | | X
Jones, 2020^131^ | Poor | 212 | Pre-post | Navajo families with young children | Yes | | X
Rivera, 2023^144^ | Poor | 13 | Pre-post | Adults ages 35-75 years with hypertension | No | X
Intervention assessed and addressed multiple social risk factors (Multidomain)
Berkowitz, 2018^122^ | Poor | 141 | Pre-post | Primary care patients | Yes | | | | X
Gottlieb, 2018^128^ | Poor | 1237 | Pre-post | Parents/caregivers of children | Yes | | | IG1 | IG2
Gottlieb, 2020^129^ | Poor | 639 | Pre-post | Parents/caregivers of children | Yes | | | IG1 | IG1, IG2
Renaud, 2023^143^ | Poor | 54,471 | Pre-post | Medicare and Medicaid beneficiaries with 2 or more ED visits in the past year | Yes | | | IG1, IG2 | IG1, IG2, IG3
Seligman, 2015^135^ | Poor | 687 | Pre-post | Adults with diabetes | No | X
Shankar, 2022^136^ | Poor | 140 | Pre-post | High ED utilizers | Yes | | | | X
Singer, 2022^137^ | Poor | 216 | Pre-post | Medicaid patients at a FQHC | Yes | | | | X
Slagel, 2022^120^ | Poor | 47 | NRSI | Adults with diet-related condition(s) | Yes | | X
Wu, 2019^118^ | Poor | 4917 | Cluster RCT | Chronically ill adults at high risk for future hospitalization | No | | | | X

* Quality rating was applied only to the outcomes and related analyses relevant to this review, which may differ from the primary aim of the study. Thus, studies could have Fair or Good quality methods for their primary aim, which would not be reflected in our rating

† Participants were screened for food insecurity as part of the study enrollment process (and may have also been screened for other social needs)

‡ Relevant outcomes only available on the subgroups of participants with diabetes

Abbreviations: FQHC=Federally Qualified Health Center; IG=intervention group; NRSI=nonrandomized studies of interventions; RCT=randomized controlled trial

Figure 3 Percent Reporting Food Insecurity at Longest Followup, Key Question 4

Abbreviations: CG=control group; CI=confidence interval; cRCT=crossover randomized controlled trial; IG=intervention group; FS=food security; FUP=followup (months); NRSI=nonrandomized studies of interventions; RcoT=randomized crossover trial; RR=risk ratio.

Note: Six additional studies not shown in this table reported outcomes related to food security, but either did not report detailed results sufficient for calculating the percent with food insecurity for all relevant groups or timepoints,^145^ reported percent change in those reporting food insecurity,^128^ reported a continuous measure of food barriers,^137,142,144^ or reported only food-medication tradeoffs.^135^

Figure 3 is a forest plot depicting the percent of participants reporting food insecurity at longest followup for each study included for Key Question 4. Figure 3 is discussed in the Results section for Key Question 4.

Nineteen additional studies (n=70,537) reported a food security outcome but were rated as poor quality for the specific outcomes of interest for this review; improvements in food security were rarely reported to be statistically significant.^118,120–123,125,126,128–132,136–138,140,143–145^ Effect sizes were wide ranging, typically reported after 6 months or less, and trended in the direction of benefit in all studies but one.^118^ Eight studies (n=3,535) did not report a food security outcome; all of these included the provision of food or food vouchers but had other study aims, such as healthier diets or physiologic outcomes specific to the study population.^119,124,127,132–134,139,141^ The consumption of fruits and vegetables generally increased after participation in interventions that included either food boxes or vouchers. For other outcomes, one pre-post study reported improvements in depression and self-rated health (e.g., 69% rated their health as excellent or very good after receiving 23 weekly food boxes, compared with 52% at baseline [p=0.039]).^130^ There was minimal impact on physiologic outcomes (blood pressure, lipid levels, glucose levels) or acute healthcare utilization, although these outcomes were never reported by more than three studies.

### Detailed Results

#### Overview of Studies

We included 29 studies (n=74,292) that examined interventions to address food insecurity, including one randomized crossover trial (n=44),^117^ one cluster RCT (n=4,917),^118^ three NRSIs that included control groups (n=513),^119,120,142^ and 24 pre-post single cohort studies without a control group (n=68,818).^121–127^ ^128–141,143–145^ Only two studies were rated as fair quality,^117,142^ and the remaining were rated as poor quality for the outcomes of interest to this review. The studies were grouped into three intervention categories: those addressing food security only,^117,119,121,124,127,130,132–134,138–142^ food security + nutrition education,^123,125,126,131,144,145^ and those addressing multiple domains (“multidomain”)^118,120,122,128,129,135–137,143^ (Table 10).

#### Study Design and Population

Interventions in 14 studies focused only on ameliorating food insecurity, without extensive nutrition education or addressing other social determinants of health or medical needs (Table 11, Table 12).^117,119,121,124,127,130,132–134,138–142^ This group included both of the fair-quality studies. One was a randomized crossover trial (n=44) among adult primary care patients with diabetes.^117^ Potential participants were screened via the Hunger Vital Sign in a primary care setting, and those who screened positive for food insecurity were enrolled, then compared on a wide range of outcomes between the end of the intervention (on-meal) period and the end of participants’ off-meal phase. The other fair-quality study was an NRSI that compared children in families who participated in a mobile food pantry with a propensity-score matched cohort of pediatric patients from the same neighborhood as the mobile pantry participants, or from nearby neighborhoods not offering a mobile pantry program.^142^

Table 11 Study Characteristics, Food Security Only Interventions, Key Question 4

Study (Quality rating) | N | Study design | Population | Setting | Screening | FI screener | Intervention | Duration (weeks) | % Food Insecurity and assistance
Berkowitz, 2019^117^ (Fair) | 44 | Randomized crossover trial | Patients with diabetes | Primary care | FI only | Hunger Vital Sign | IG1: Home delivery of medically tailored meals | 12 | Food Insecurity: 100; SNAP: 66.7; WIC: NR
Woo Baidal, 2023^142^ (Fair) | 176 | NRSI | Families with children | Primary care | Multiple risk factors | Hunger Vital Sign | IG1: Twice-monthly food selection at mobile pantry to provide ~12 meals per household member with SNAP/WIC enrollment assistance | 26 | Food Insecurity: 100
Aiyer, 2019^121^ (Poor) | 242 | Pre-post | Adult patients and parents of pediatric patients | Primary care, Pediatric primary care | FI only | Hunger Vital Sign | IG1: “Food Rx” card for 30+ lbs produce + 4 non-perishable healthy items, for redemption at food pantry every 2 weeks for 12 redemptions, plus educational materials | 26 | Food Insecurity: 100; SNAP: 9.5; WIC: 3.3
Cohen, 2017^124^ (Poor) | 177 | Pre-post | SNAP enrolled adults | Primary care, Pediatric primary care | FI only | Current SNAP enrollment | IG1: Educational materials about Double Up Food Bucks (DUFB) + one-time $10 voucher for farmers market | 0.14 | Food Insecurity: 79.6; SNAP: 100; WIC: 29.4
Freedman, 2013^127^ (Poor) | 45 | Pre-post | FQHC patients with diabetes | Primary care | NA (no screening) | NA | IG1: Vouchers for up to $50 for on-site farmers’ market | 22 | Food Insecurity: 51.2; SNAP: NR; WIC: NR
Izumi, 2020^130^ (Poor) | 80 | Pre-post | FQHC patients | Primary care | NA (no screening) | NA | IG1: Weekly food box | 23 | Food Insecurity: 87; SNAP:; WIC:
Kempainen, 2023^140^ (Poor) | 281 | Pre-post | Adults with type 2 diabetes and food insecurity | Primary care | FI only | Hunger Vital Sign | IG1: Home-delivered ethnically tailored food boxes biweekly for 24 weeks, plus information and assistance with food resources (including SNAP) | 24 | Food Insecurity: 100
Kempainen, 2023^140^ (Poor) | 281 | Pre-post | Adults with type 2 diabetes and food insecurity | Primary care | FI only | Hunger Vital Sign | IG2: Information and assistance with food resources (including SNAP) | 24 | Food Insecurity: 100
Morales, 2016^119^ (Poor) | 290 | NRSI | Pregnant women | Obstetrics | FI only | NR | IG1: Referrals & support with community food resources or government assistance programs (e.g., SNAP, WIC) | NR | Food Insecurity: 100; SNAP: NR; WIC: 87
Orsega-Smith, 2020^132^ (Poor) | 41 | Pre-post | Adults who are Medicaid enrollees, overweight, or have 2+ children | Pediatric primary care | FI only | Current federal food assistance enrollment or Yes to “In the past 12 months, did you or others in your home ever cut the size of meals, skip meals, and/or buy fewer healthy foods such as fruit and vegetables because there was not enough money for food?” | IG1: 24 Biweekly produce boxes, ~15-25 lbs/month with nutrition education (format, intensity NR) | 52 | Food Insecurity: 100; SNAP: NR; WIC: NR
Ranjit, 2023^141^ (Poor) | 2028 | Pre-post | Adults who are food insecure and diagnosed with prediabetes/diabetes, hypertension, or obesity | Other medical | NA (no screening) | NA | IG1: Twice monthly redemption of produce and other foods at food pantry | NR | Food Insecurity: 82.9; SNAP: 22.5; WIC: NR
Saxe-Custack, 2019^133^ (Poor) | 261 | Pre-post | Parents of children aged 7 to 18 (regardless of food insecurity status) | Pediatric primary care | NA (no screening) | NA | IG1: Fruit and vegetable voucher for $15 by pediatricians at every clinic visit | 26 | Food Insecurity: 48.7; SNAP: 56.3; WIC: NR
Scher, 2022^134^ (Poor) | 340 | Pre-post | Adults | Primary care | FI only | Hunger Vital Sign | IG1: Twice monthly food box delivery for 12 months | 52 | Food Insecurity: 100; SNAP: NR; WIC: NR
Wetherill, 2018^138^ (Poor) | 80 | Pre-post | Uninsured patients attending a chronic disease clinic | Primary care, Other medical | NA (no screening) | NA | IG1: Up to 7 monthly food prescription boxes (DASH diet) | NR | Food Insecurity: 87; SNAP: 55; WIC: NR
Xie, 2021^139^ (Poor) | 353 | Pre-post | Adults with diabetes (subgroup) | Primary care, Social service agencies, Academic site | FI only | Hunger Vital Sign or clinicians’ informal understanding of patients’ SES situation | IG1: Vouchers for $40/month for fruits and vegetables at local grocery store | 52 | Food Insecurity: 100; SNAP: 100; WIC: NR

Abbreviations: DASH=Dietary Approaches to Stop Hypertension; DUFB=Double Up Food Bucks; FI=food insecurity; Food Rx=food prescription; FQHC=Federally Qualified Health Center; IG=intervention group; NA=not applicable; NR=not reported; NRSI=nonrandomized studies of interventions; SES=socioeconomic status; SNAP=Supplemental Nutrition Assistance Program; WIC=Supplemental Nutrition Program for Women, Infants, and Children

Table 12 Population Characteristics, Food Security Only Interventions, Key Question 4

Study (design) | Age, Mean (Range) | % Women | % Race/Ethnicity | % Other Assistance | Other SES
Berkowitz, 2019^117^ (RcoT) | 58.5 (NR) | 69 | Asian: NR; Black: 26.2; Hispanic/Latino: 16.7; Native Amer: NR; White: 54.8; Multiracial: NR | Medicaid: 28.6; Medicare: 4.8 | Median income: 140% of federal poverty level; Born outside USA: 31%; Education: < HS: 7%, HS: 24%, > HS: 69%; Other insurance: Private: 14%, Dual: 52%
Woo Baidal, 2023^142^ (NRSI) | 1.7 (<72) | 51.1 | Asian: NR; Black: NR; Hispanic/Latino: 85.8; Native Amer: NR; White: NR; Multiracial: NR | NR | NR
Aiyer, 2019^121^ (Pre-post) | 47.3 (NR) | 79.1 | Asian: NR; Black: 3.5; Hispanic/Latino: 79.7; Native Amer: NR; White: NR; Multiracial: NR | Medicare/Medicaid: 7.0 | Household size, mean (SD) 2.7 (1.4) adult, 1.9 (1.5) children
Cohen, 2017^124^ (Pre-post) | NR (29-46) | 85.3 | Asian: NR; Black: 59.9; Hispanic/Latino: 9.0; Native Amer: NR; White: 29.4; Multiracial: NR | Other food assistance: 2.3 | English speaking: 95%; Education: College/tech school: 37%, College grad or higher: 11%; Household size, mean (SD): 3.2 (1.7); ≥1 child
Freedman, 2013^127^ (Pre-post) | 63.6 (34 −88) | 82.9 | Asian: 0; Black: 92.7; Hispanic/Latino: NR; Native Amer: 0; White: 7.3; Multiracial: NR | SNAP, WIC, and/or free or reduced lunch: 53.7; Financial assistance (TANF, Medicaid, Disability, SSI): 36.6 | Education: < HS: 29%, HS or GED: 44%, Some college or tech school: 15%, ≥College graduate: 12%; Annual household income=1 year: 10%, Not employed for wages: 7%
Izumi, 2020^130^ (Pre-post) | 46 (NR) | 91.7 | Asian: NR; Black: 4.2; Hispanic/Latino: 52.1; Native Amer: NR; White: 37.5; Multiracial: NR | SNAP or WIC: 68.8 | Education: bachelor’s degree: 8%; Income: <10K: 25%, 10K-19,999: 40%, 20K-29,999: 25%, <30K: 6%; Household size, mean (SD): 3.8 (2.0)
Kempainen, 2023^140^ (Pre-post) | 55.6 (21-70) | NR | Asian: NR; Black: 67; Hispanic/Latino: 3; Native Amer: 9; White: 21; Multiracial: NR | NR | Education: No HS degree: 27%, HS degree or GED: 30%, Some college or tech school: 29%, College graduate: 14%; Employment: Disabled: 50%, Part-time: 13%, Full-time: 7%, Unemployed: 13%,Retired: 11%, Homemaker/other: 6%
Morales, 2016^119^ (NRSI) | 30.1 (NR) | 100 | Asian: NR; Black: 6.9; Hispanic/Latino: 84.8; Native Amer: NR; White: 4.8; Multiracial: NR | NR | Other insurance: Private: 48%, Uninsured: 3%
Orsega-Smith, 2020^132^ (Pre-post) | NR (NR) | NR | Asian: NR; Black: NR; Hispanic/Latino: 14; Native Amer: NR; White: 90; Multiracial: NR | NR | Household size, mean (SD): 2.2 (0.8) adults, 2.5 (1.3) children
Ranjit, 2023^141^ (Pre-post) | 57.1 (NR) | 69.0 | Asian: NR; Black: 31.9; Hispanic/Latino: 55.8; Native Amer: NR; White: NR; Multiracial: NR | NR | Education: HS diploma: 22.5%; Employment: Full time: 17.9%, Part time: 13.2%, Homemaker/ unemployed/ retired/ other: 68.9%
Saxe-Custack, 2019^133^ (Pre-post) | 40.0 (NR) | 89.3 | Asian: NR; Black: 77.4; Hispanic/Latino: NR; Native Amer: NR; White: 15.3; Multiracial: NR | Free and reduced-price lunch: 58.2 | Education: ≤HS: 33%, Some college/technical school/associates: 40%, bachelor’s degree: 15%, Graduate degree: 8%, Other/NR: 4%
Scher, 2022^134^ (Pre-post) | 60.3 (NR) | 65.6 | Asian: NR; Black: 86.3; Hispanic/Latino: NR; Native Amer: NR; White: NR; Multiracial: NR | NR | NR
Wetherill, 2018^138^ (Pre-post) | 51.7 (NR) | 66 | Asian: NR; Black: NR; Hispanic/Latino: NR; Native Amer: NR; White: NR; Multiracial: NR | NR | Income <$15,000: 74%
Xie, 2021^139^ (Pre-post) | 61.2 (NR) | 72.0 | Asian: NR; Black: 81.9; Hispanic/Latino: 4.8; Native Amer: NR; White: 11.9; Multiracial: NR | Medicare: 28; Medicare advantage: 2; Medicaid: 23 | Other insurance: Private: 12%, Other (uninsured, VA, or unlisted): 15%

Abbreviations: GED=general equivalency diploma; HS=high school; NR=not reported; RcoT=randomized crossover trial; SD=standard deviation; SES=socioeconomic status; SNAP=Supplemental Nutrition Assistance Program; SSI=Supplemental Security Income; TANF=Temporary Assistance for Needy Families; VA=Veterans Affairs; WIC=Supplemental Nutrition Program for Women, Infants, and Children

Of the remaining food security-only studies, 11 were pre-post studies in a single cohort,^121,124,127,130,132–134,138–141^ and one was a nonrandomized study that employed a propensity-matched control group of people referred versus not referred to Food for Families,^119^ an intervention for pregnant women that provided referrals and application support to community-based food resources and government assistance programs. One of the pre-post studies was an RCT comparing two active treatment conditions, but because this review did not include comparative effectiveness studies, we treated this study as having two separate pre-post studies (i.e., one study for each intervention group).^140^ Collectively, these 14 studies covered a range of populations, including broad-based or low-income adult populations,^117,121,124,130,132,134^ pregnant women,^119^ adults with diabetes,^127,139,140^ adults with any of a number of chronic conditions or cardiovascular risk factors,^138,141,145^ Medicare and Medicaid beneficiaries with two or more ED visits in the past year, and families with children.^133,142^ Nine of these studies identified participants with food insecurity via screening in medical settings.^117,119,121,124,132,134,139,140,142^ The remaining studies used a variety of recruitment methods (e.g., clinician referral, participant self-referral in response to flyers, or recruitment of all clients at a specific clinic, food pantry, or community program).

Six studies focused on both ameliorating food insecurity and providing nutrition education to improve diet quality; all were pre-post studies (Tables 13 and 14).^123,125,126,131,144,145^ We looked only at the food insecurity outcomes of these studies as dietary counseling may have had an effect on health independent of food security. Five of the studies were limited to people with chronic conditions or deemed at risk for chronic conditions (e.g., meeting criteria for obesity, prediabetes, diabetes, hypertension, or dyslipidemia),^123,125,126,144,145^ and one of these five was also limited to families with young children.^123^ The remaining study was conducted among Navajo families with young children.^131^ Three of these studies recruited participants via screening for food insecurity.^125,126,131^

Table 13 Study Characteristics, Food Security + Nutrition Education Interventions, Key Question 4

Study (Quality rating) | N | Study design | Population | Setting | Screening | FI screener | Intervention | Duration (weeks) | % Food Insecurity and assistance
Byker Shanks, 2022^123^ (Poor) | 43 | Pre-post | Adults at risk for chronic disease | Community-based | NA (no screening) | NA | IG1: Weekly provision of unprocessed food from local food bank, plus 8 biweekly 20-to 30-minute nutrition education sessions | 16 | Food Insecurity: 93.0; SNAP: NR; WIC: NR
Cook, 2021^125^ (Poor) | 185 | Pre-post | Adults with risk factor for diet-related chronic condition | Community-based, Primary care | NA (no screening) | NA | IG1: Group-based nutrition and cooking education plus subsidies for fresh produce ($1/day/family member) | 26 | Food Insecurity: 63.3; SNAP: 57.0; WIC: 4.7
Fischer, 2022^126^ (Poor) | 25 | Pre-post | Families with young children and diet-related chronic disease risk factor | Pediatric primary care | FI only | Hunger Vital Sign | IG1: 24 biweekly fruit and vegetable delivery plus ~24 hours of virtual nutrition education | 52 | Food Insecurity: 100; SNAP: 64; WIC: 56
Hager, 2023^145^ (Poor) | 3881 | Pre-post | Adults with, or at risk for, poor cardiometabolic health | Primary care | NA (no screening) | NA | IG1: 22 produce prescription programs across the U.S. with nutrition education (median subsidies, $63/month) | 17 to 43 | Food Insecurity: 52.6; SNAP: 62.7; WIC: 82.6
Jones, 2020^131^ (Poor) | 212 | Pre-post | Navajo families with young children | Community-based, Primary care, Other medical, Social service agencies | FI only | Varied by site. Indian Health Service Food Insecurity Screening Questionnaire at some sites; others NR | IG1: Fruit and vegetable prescriptions valued at up to $5/day plus monthly health information sessions | 26 | Food Insecurity: 80; SNAP: 68; WIC: 66
Rivera, 2023^144^ (Poor) | 13 | Pre-post | Adults ages 35-75 years with hypertension | Other medical | FI only | NA | IG1: 16-week dietitian-led lifestyle and cooking intervention with medically tailored meal delivery | 16 | Food Insecurity: 100; SNAP: 69.2; WIC: NR

Abbreviations: FI=food insecurity; IG=intervention group; NA=not applicable; NR=not reported; SNAP=Supplemental Nutrition Assistance Program; WIC=Supplemental Nutrition Program for Women, Infants, and Children

Table 14 Population Characteristics, Food Security + Nutrition Education Interventions, Key Question 4

Study (design) | Age, Mean (Range) | % Women | % Race/Ethnicity | % Other Assistance | Other SES
Byker Shanks, 2022^123^ (Pre-post) | 46.9 (NR) | 78.4 | Asian: NR; Black: NR; Hispanic/Latino: NR; Native Amer: NR; White: NR; Multiracial: NR | NR | Education: ≤HS: 41%, Some college: 35%, 2- or 4-year degree: 22%; Income: 50K: 3%; Employment: 1-10 hr/wk: 3%, 11-29 hr/wk: 5%, ≥30 hr/wk: 38%, Temp/seasonal job: 3%, Looking for work: 19%, Not employed, not looking for work: 8%, Retired, disabled, homemaker, or full-time student: 19%, Other: 5%; Healthcare coverage: 92%
Cook, 2021^125^ (Pre-post) | NR (NR) | 72.0 | Asian: NR; Black: 78.7; Hispanic/Latino: 9.3; Native Amer: NR; White: 9.3; Multiracial: 1.9 | Public health insurance: 47; Any public assistance: 62 Reduced price or free lunch: 2 | Household income: <25k: 77%, 25k–34,999: 11%, 35k–49,999: 6%, ≥50k: 6%; Employment: Full time: 14%, Part-time: 10%, Retired: 14%, Student: 3%, Not employed/homemaker: 24%, On disability: 33%, Other: 3%; Other insurance: Private insurance: 9%, Through employer: 4%, Uninsured: 33%, Other: 6.5%
Fischer, 2022^126^ (Pre-post) | 29.9 (NR) | 100 | Asian: 0; Black: 100; Hispanic/Latino: NR; Native Amer: 0; White: 0; Multiracial: 0 | Free/reduced price school lunch: 32; Supplemental security income: 28; Temporary Assistance for Needy Families (TANF): 56 | Employment: Full-time: 16%, Part-time: 24%, Student or apprentice: 8%, Unemployed: 40%, Self-employed: 4%, Prefer not to say: 8%; Education: <HS: 12%, HS or GED: 48%, Some college: 28%, College grad: 4%, Prefer not to say: 8%; Income: <10K: 40%, 10,001-25k: 12%, 25,001-50k: 16%, Prefer not to say: 32%; Household size, median: 1 adult, 3 children ages 0-17
Hager, 2023^145^ (Pre-post) | 54.4 (adult); 9.2 (child) (NR) | 61.5 | Asian: NR; Black: 29.8; Hispanic/Latino: 45.1; Native Amer: NR; White: 19.9; Multiracial: NR | Medicaid/CHIP: 79 | Insurance status: Medicaid/CHIP: 79%, Private: 3.9%, Uninsured: 11.4%, Other: 5.5%; Parent/caregiver employment: Full time: 18.5%, Part time: 24.3%, Unemployed: 38.0%, Other: 19.2%
Jones, 2020^131^ (Pre-post) | 3.96 (of children) (0-6 [of children]) | 50 | Asian: 0; Black: 0; Hispanic/Latino: NR; Native Amer: 100; White: 0; Multiracial: NR | Food Distribution Program on Indian Reservations & WIC: 1 | Median household size: 5
Rivera, 2023^144^ (Pre-post) | 58.9 (35-75) | 76.9 | Asian: 0; Black: 92.3; Hispanic/Latino: NR; Native Amer: 0; White: 7.7; Multiracial: NR | NR | Employment status: Full/part-time: 15.4%, Unemployed due to health status: 46.2%, Retired: 23.1%, Student: 15.4%; Total income/month: <1500: 23.1%, 1500-2000: 76.9%; Education: < HS diploma: 30.8%, HS grad or GED: 38.5%, >HS grad: 30.8%

Abbreviations: CHIP=Child Health Insurance Program; GED=general equivalency diploma; HS=high school; NR=not reported; SES=socioeconomic status; TANF=Temporary Assistance for Needy Families; WIC=Supplemental Nutrition Program for Women, Infants, and Children

Nine studies offered multidomain interventions designed to assess and address (as needed) a wide range of social needs, including food insecurity (Tables 15 and 16).^118,120,122,128,129,135–137,143^ Three of these studies were RCTs comparing two active treatment conditions, but because this review did not include comparative effectiveness studies, we treated these studies as separate pre-post studies (i.e., one study for each intervention group).^128,129,143^ Four other multidomain intervention studies were pre-post studies,^122,135–137^ one was a nonrandomized study in which intervention and control participants were recruited from different study sites,^120^ and one was a cluster RCT.^118^ Some of these studies included broad populations (primary care patients,^122^ parents or caregivers of children,^128,129^ Medicaid patients at a federally qualified health center [FQHC]^137^), while recruitment for others was based on health conditions (adults with diabetes^135^ or diet-related conditions,^120^ high levels of ED utilization,^136,143^ or chronic illnesses and high risk for future hospitalization^118^). Eligible participants for seven of the studies were identified via screening for social needs.^120,122,128,129,136,137,143^

Table 15 Study Characteristics, Multidomain Interventions, Key Question 4

Study (Quality rating) | N | Study design | Population | Setting | Screening | FI screener | Intervention | Non-food components^*^ | Duration (weeks) | % Food Insecurity and assistance
Berkowitz, 2018^122^ (Poor) | 141 | Pre-post | Primary care patients | Primary care | Multiple risk factors | HFSS-6 | IG1: Patient navigation | Housing, Transportation, Other: Cost-related medication underuse | 8.7 | Food Insecurity: 40.4; SNAP: NR; WIC: NR
Gottlieb, 2018^128^ (Poor) | 1237 | Pre-post | Parents/caregivers of children | Pediatric urgent care | Multiple risk factors | 2 items: How stressful do you find concerns that: (1) food will run out before you get money or food stamps to get more? And (2) not having enough healthy food (fruits, vegetables, and whole grains) to eat every day? | IG1: Met with patient navigators every 2 weeks for up to 3 months to address a wide range of social needs | Housing, Transportation, Utilities, Childcare, Legal services, Other: Medical or tax preparation | 13 | Food Insecurity: 39.6; SNAP: NR; WIC: NR
Gottlieb, 2018^128^ (Poor) | 1237 | Pre-post | Parents/caregivers of children | Pediatric urgent care | Multiple risk factors | | IG2: Preprinted handouts listing local community-based social service resources | Housing, Transportation, Utilities, Childcare, Legal services, Other: Medical or tax preparation | 0.14 | Food Insecurity: 39.6; SNAP: NR; WIC: NR
Gottlieb, 2020^129^ (Poor) | 639 | Pre-post | Parents/caregivers of children | Pediatric urgent care | Multiple risk factors | FI item: Running out of food before having enough money or food stamps to buy more | IG1: In-person navigation every 2 weeks up for up to 3 months to address a wide range of social needs | Housing, Transportation, Employment, Utilities, Childcare, Legal services, Other: Disability interfering with work, health insurance, primary care clinician, medical or pharmacy bills, afterschool activities, bullying, adult mental or behavioral health | 13 | Food Insecurity: 37.5; SNAP: NR; WIC: NR
Gottlieb, 2020^129^ (Poor) | 639 | Pre-post | Parents/caregivers of children | Pediatric urgent care | Multiple risk factors | FI item: Running out of food before having enough money or food stamps to buy more | IG2: Written resources | | 0.14 | Food Insecurity: 37.5; SNAP: NR; WIC: NR
Renaud, 2023^143^ (Poor) | 57471 | Pre-post | Medicare and Medicaid beneficiaries with 2 or more ED visits in the past year | Other medical | Multiple risk factors | Hunger Vital Sign | IG1: Referrals + navigation + advisory board | Housing, Transportation, Utilities, Intimate partner violence | 52 | Food Insecurity: 66.4; SNAP: NR; WIC: NR
Renaud, 2023^143^ (Poor) | 57471 | Pre-post | Medicare and Medicaid beneficiaries with 2 or more ED visits in the past year | Other medical | Multiple risk factors | Hunger Vital Sign | IG2: Referrals + navigation | Housing, Transportation, Utilities, Intimate partner violence | 52 | Food Insecurity: 66.4; SNAP: NR; WIC: NR
Renaud, 2023^143^ (Poor) | 57471 | Pre-post | Medicare and Medicaid beneficiaries with 2 or more ED visits in the past year | Other medical | Multiple risk factors | Hunger Vital Sign | IG3: Community resource referrals | Housing, Transportation, Utilities, Intimate partner violence | 52 | Food Insecurity: 66.4; SNAP: NR; WIC: NR
Seligman, 2015^135^ (Poor) | 687 | Pre-post | Adults with diabetes | Community-based, Primary care | NA (no screening) | NA | IG1: Diabetes-appropriate food boxes, diabetes self-management support, and primary care referrals as needed | Other: Blood sugar monitoring, primary care referral, self-management support | 26 | Food Insecurity: 83; SNAP: NR; WIC: NR
Shankar, 2022^136^ (Poor) | 140 | Pre-post | High ED utilizers | ED | Multiple risk factors | FI items NR | IG1: Community health advocate and legal support | Housing, Transportation, Employment, Utilities, Social isolation, Legal services, Other: Caregiving help | 26 | Food Insecurity: 79.5; SNAP: NR; WIC: NR
Singer, 2022^137^ (Poor) | 216 | Pre-post | Medicaid patients at a FQHC | Primary care | Multiple risk factors | FI item: In the past year, have you or any family members you live with been unable to get food when really needed? | IG1: Care coordination | Housing, Transportation, Employment, Education, Utilities, Language, Social isolation, Intimate partner violence, Childcare, Legal services | 26 | Food Insecurity: 21.3; SNAP: NR; WIC: NR
Wu, 2019^118^ (Poor) | 4917 | Cluster RCT | Chronically ill adults at high risk for future hospitalization | Community-based | NA (no screening) | NA | IG1: Support for community-based organizations to make referrals to community resources and social services | Housing, Transportation, Employment, Utilities | 52 | Food Insecurity: NR; SNAP: NR; WIC: NR
Slagel, 2022^120^ (Poor) | 47 | NRSI | Adults with diet-related condition(s) | Community-based, Primary care | FI only | HFSS-6 | IG1: Fruit & vegetable vouchers (1$/day/household member) plus 10 60- to 90-minute food/nutrition classes, 4 financial literacy classes | Other: Food and nutrition classes, Financial literacy | 26 | Food Insecurity: 60.7; SNAP: NR; WIC: NR

* Non-food insecurity components are domains listed by authors as being addressed; some studies did not provide an exhaustive list of all domains assessed or addressed, and domains were typically addressed only as needed by the study participant

Abbreviations: ED=emergency department; FI=food insecurity; FQHC=Federally Qualified Health Center; HFSS=Household Food Security Survey; IG=intervention group; NA=not applicable; NR=not reported; NRSI=nonrandomized studies of interventions; RCT=randomized controlled trial; SNAP=Supplemental Nutrition Assistance Program; WIC=Supplemental Nutrition Program for Women, Infants, and Children

Table 16 Population Characteristics, Multidomain Interventions, Key Question 4

Study (design) | Age, Mean (Range) | % Women | % Race/Ethnicity | % Other Assistance | Other SES
Berkowitz, 2018^122^ (Pre-post) | 59.7 (NR) | 64.9 | Asian: NR; Black: 28.4; Hispanic/Latino: 6.3; Native Amer: NR; White: 50.4; Multiracial: NR | Medicare: 11.5; Medicaid: 50.4 | Education: < HS: 13%, HS or GED: 49%, >HS: 38%; Other insurance: Commercial: 30%, Self-pay: 8%
Gottlieb, 2018^128^ (Pre-post) | NR (NR) | NR | Asian: NR; Black: NR; Hispanic/Latino: 53.8; Native Amer: NR; White: NR; Multiracial: NR | NR | Household income < $30,000/year: 80%
Gottlieb, 2020^129^ (Pre-post) | NR (18-74) | 88.4 | Asian: NR; Black: 9.0; Hispanic/Latino: 82.0; Native Amer: NR; White: 2.9; Multiracial: | NR | Household income <$30,000/year: 88%; Caregiver education level: <HS: 51%, HS grad or GED: 28, Some college or college grad: 21%
Renaud, 2023^143^ (Pre-post) | NR (NR) | 65.6 | Asian: NR; Black: 27.1; Hispanic/Latino: 13.5; Native Amer: NR; White: 43.6; Multiracial: NR | 100% enrolled in Medicaid and/or Medicare | NR
Seligman, 2015^135^ (Pre-post) | 56.6 (NR) | 74 | Asian: NR; Black: 12; Hispanic/Latino: 53; Native Amer: NR; White: 25; Multiracial: NR | NR | Education: > HS or GED: 41%, HS or GED: 21%, < HS or GED: 37%
Shankar, 2022^136^ (Pre-post) | 47.7 (22-75) | 57.9 | Asian: NR; Black: 60.7; Hispanic/Latino: 5.7; Native Amer: NR; White: 30.0; Multiracial: NR | Medicaid: 65; Medicare: 21 | Other insurance: Commercial: 14%
Singer, 2022^137^ (Pre-post) | NR (NR) | 75.1 | Asian: 29.1; Black: 22.7; Hispanic/Latino: 30.6; Native Amer: 1.4; White: 14.8; Multiracial: NR | Medicaid: 100 | Primary language: English: 56%, Spanish: 22%, Hmong: 20%, Other: 2%; Unemployed: 54%; Unstable housing: 24%; Lack transportation: 26%
Slagel, 2022^120^ (NRSI) | 49.86 (NR) | 89.3 | Asian: NR; Black: NR; Hispanic/Latino: 35.7; Native Amer: NR; White: NR; Multiracial: NR | Receiving federal assistance: 53.6 | Uninsured: 85.7%; Household size, mean (SD): 2.3 (2.1)
Wu, 2019^118^ (Cluster RCT) | 62 (NR) | 64 | Asian: 1; Black: 55; Hispanic/Latino: 1; Native Amer: 0; White: 39; Multiracial: NR | Medicare: 65 | NR

Abbreviations: GED=general equivalency diploma; HS=high school; NR=not reported; NRSI=nonrandomized studies of interventions; RCT=randomized controlled trial; SD=standard deviation; SES=socioeconomic status

Across all KQ4 studies that reported race and ethnicity, 30 percent of the included participants were Black, 18 percent were Hispanic, and 41 percent were White. One study was limited to people of the Navajo Nation. Overall, there appeared to be minimal representation of other races or ethnicities such as Native Americans or of people of Asian descent.

#### Interventions

Detailed descriptions of the interventions for all studies are available in Appendix D Table 3. Of the 14 interventions addressing only food insecurity, the fair-quality randomized crossover trial provided home delivery of medically tailored meals for 12 weeks,^117,140^ and eight others included weekly, biweekly, or monthly food boxes for 6 to 12 months.^121,130,132,134,138,141,142^ One of these, among patients attending a chronic disease clinic, was specifically tailored to the Dietary Approaches to Stop Hypertension (DASH) diet, and the box was delivered directly to patient homes rather than requiring pickup.^138^ Four interventions supplied vouchers or subsidies for food, ranging in amount from $15 per clinic visit to $40 per month, which could be redeemed at local stores or farmers markets.^124,127,133,139^ The remaining study that narrowly addressed food security relied on referrals to community and government assistance programs and helped participants with the application process.^119^

Among the six studies that addressed food insecurity supplemented by nutrition counseling, one provided delivery of medically tailored meals for 16 weeks,^144^ two included the provision of biweekly food boxes,^123,126^ and the other three included vouchers for $1/day/family member, a median of $63 per month, and up to $5 per day.^125,131,145^ Nutrition counseling typically involved monthly to biweekly sessions with information on healthy diet and food preparation, and often included food tastings, cooking demonstrations, and counseling techniques such as goal-setting for improved dietary intake. One intervention was delivered online and offered approximately 24 hours of virtual nutrition education with content that was culturally tailored for the African American community.^126^

The multidomain interventions involved a social needs assessment and interventions targeted to participants’ social needs. Most of the interventions involved helping participants identify and enroll in appropriate local and federal resources related to a wide range of social needs, such as housing, transportation, childcare, and legal services.^118,120,122,128,129,135–137,143^ One of these was a large (n=57,471) demonstration project by CMS that assigned patients who had screened positive for at least one social risk factor and had two or more ED visits in the previous year into three groups: 1) referral and information only, 2) referral plus the option for navigation, and 3) referral, navigation, and an organizational advisory board composed of beneficiaries, healthcare partners, and community service organizations that was charged with identifying and addressing gaps in community services relative to community needs.^143^ Patient navigators, care coordinators, and community health advocates are examples of interventionists who implemented the navigation and application support activities. Two interventions focused primarily on food security, along with some other complementary components.^120,135^ One of these two included the provision of diabetes-appropriate food boxes to patients with diabetes and food insecurity along with diabetes self-management support, blood sugar monitoring, and medical referrals.^135^ The other intervention that had a relatively large emphasis on food and food security centered on the provision of vouchers to purchase produce, along with nutrition classes and financial literacy education.^120^

#### Risk of Bias

Appendix A Figure 2 shows the risk of bias ratings for the major risk of bias domains. The fair-quality randomized crossover trial was downgraded from good for the small study size (n=44), lack of allocation concealment, and differential followup between the on-meals and off-meals phases (70% completed assessments after on-meals vs. 89% after off-meals).^117^ The fair-quality NRSI was downgraded from good primarily because unmeasured confounders could be the causal factor for differences between groups, due to the lack of randomization.

Two studies were nonrandomized studies that included control groups, but both were rated as poor quality.^119,120^ For the study of a food security-only intervention with a propensity-matched control group, the main threat to validity was a lack of information about whether co-interventions were balanced across intervention groups (e.g., whether the groups received comparable prenatal medical care and whether use of medications for blood pressure was comparable across groups).^119^ It was particularly concerning that there was no information on the comparability of blood pressure medication use across groups when the primary outcome was blood pressure. Blood pressure is monitored closely during pregnancy, and treatment is undertaken when blood pressure becomes elevated, so we had limited confidence that changes in blood pressure were related to food program referrals rather than medication use. In addition, it would be very difficult to control for all confounding factors that led some patients to be referred to a food security program versus not referred.

The other nonrandomized study of a multidomain intervention recruited intervention and control participants from separate locations.^120^ The main concerns with this study were high attrition (38% to 42%) and an imbalance of population characteristics that suggest the study groups may not have been comparable (e.g., 55% of intervention participants were Hispanic vs. 0% in the control group). Intervention participants were recruited from both FQHCs and other community-based organizations, while control participants were recruited from a single FQHC, which lowered our confidence that the assembled groups were comparable. This study also had a very small sample (n=18 participants analyzed), further limiting our confidence that the results were broadly applicable.

We also rated as poor quality a cluster RCT that examined a multidomain intervention.^118^ For the purposes of this review, this study was rated only for the food security outcome, which was not its primary outcome, and ascertainment of food insecurity was not described. Furthermore, participants were randomized based on the assignment of the community-based organization that was closest to where they lived, but we were concerned that participants might have chosen to access an organization based on previous experience with it or because of its specific focus or offerings, rather than on location only, potentially compromising the comparability of the intervention groups at baseline.

None of the pre-post studies reported more than one time point prior to and after the intervention, so all were rated as poor quality, akin to high risk of bias. The lack of multiple timepoints to establish a robust baseline estimate of food insecurity led to low confidence that the intervention elicited the changes observed in these studies, rather than confounding factors such as families’ independent efforts to obtain food and food resources. Included among the pre-post studies are four randomized comparative effectiveness trials, treated as pre-post studies with multiple arms for the purposes of this review.^128,129^ ^140,143^ In addition, three nonrandomized studies assembled comparison groups that we felt were not comparable with the intervention group to the point of having a high probability of resulting in misleading effects for the purposes of this review—for example, those that matched individuals screening positive for food insecurity with a historic control matched via medical records data, but without food insecurity screening information, or those that compared outcomes of patients who opted into a program with those who did not opt in.^134,137,141^ In these cases, we retained the intervention group data and treated it as a pre-post study.

In addition to the above concerns, an issue across almost all studies was uncertainty about the assessment windows for the outcome of percent with food insecurity. The HFSS tools have 12-month and 30-day versions, but the included studies rarely reported which of these versions were used at either timepoint. If a 12-month version was used at both timepoints (which is the most widely used version) and the followup occurred after less than 12 months, then the assessment windows overlap and add uncertainty to the effect estimates. If they changed the followup measure to only report on food security status since the baseline questionnaire, or on the past 30 days, then the asymmetric time windows introduce bias that could make the intervention appear to have a larger effect, at least for pre-post studies without a comparison group.

#### Findings by Outcome

Food security outcomes. Twenty-one of the 29 studies included for KQ4 reported a food security outcome (Table 17 for the primary food insecurity finding of interest to this review for each study, Appendix D Table 3 for all available food security outcomes at all timepoints, Figure 3 for a forest plot showing study effect sizes).^117,118,120–123,125,126,128–132,136–138,140,142–145^ In the fair-quality randomized crossover trial (n=44), participants were less likely to be food insecure at the end of their 12-week on-meal phase compared with those in the 12-week off-meal phase (41.9% on-meal vs. 61.5% off-meal; p=0.05).^117^

Table 17 Percent With Food Insecurity at Longest Followup, Key Question 4

Study (design) Intervention Category | Quality Rating | Most intensive food component | Group | Analyzed | Follow-up (mos) | Group 1; n/N (%) | Group 2; n/N (%) | Between-group RR (95% CI)^*^ | p-value
FS only
Berkowitz, 2019^117^ (RcoT)^†^ | Fair | Free food | IG1 | All | 2.8 | On meal: 13/31 (41.9) | Off meal: 24/39 (61.5) | 0.68 (0.42 to 1.1) | 0.047
Aiyer, 2019^121^ (Pre-post) | Poor | Free food | IG1 | All | 6 | Pre: 242/242 (100) | Post: 10/172 (5.9) | NA | NR
Izumi, 2020^130^ (Pre-post) | Poor | Free food | IG1 | All | 5.3 | Pre: 42/48 (87.5) | Post: 35/48 (72.9) | NA | 0.48
Kempainen, 2023^140^ (Pre-post) | Poor | Free food | IG1 | All | 5.5 | Pre: 106/106 (100) | Post: 83/106 (78.0) | NA | NR
Kempainen, 2023^140^ (Pre-post) | Poor | Referrals | IG2 | All | 5.5 | Pre: 108/108 (100) | Post: 94/108 (87.0) | NA | NR
Wetherill, 2018^138^ (Pre-post) | Poor | Free food | IG1 | Received 4+ boxes | ≤7 | Pre: NR | Post: NR | NA | NSD
FS + Nutr Ed
Byker Shanks, 2022^123^ (Pre-post) | Poor | Free food | IG1 | All | 3.5 | Pre: 34/37 (91.9) | Post: 31/37 (83.8) | NA | NR
Fischer, 2022^126^ (Pre-post) | Poor | Free food | IG1 | All | 12 | Pre: 8/25 (32) | Post: 1/15 (7.0) | NA | 0.10
Cook, 2021^125^ (Pre-post) | Poor | Vouchers | IG1 | All | 6 | Pre: 76/120 (63.3) | Post: 36/120 (30.0) | NA | NR
Hager, 2023^145^ (Pre-post) | Poor | Vouchers | IG1 | All | 4 to 10 (varied) | Pre: 2042/3881 (52.6) | Post: NR/3428 (NR) | NA | <0.001
Jones, 2020^131^ (Pre-post) | Poor | Vouchers | IG1 | All | 6 | Pre: 161/212 (80) | Post: 79/122 (65.0) | NA | 0.001
Multidomain
Slagel, 2022^120^ (NRSI) | Poor | Vouchers | IG1 | All | 6 | IG: 5/18 (27.8) | CG: 4/10 (40.0) | 0.69 (0.24 to 2.01) | NSD
Gottlieb, 2018^128^ (Pre-post) | Poor | Appl support | IG1 | All | 4 | Pre: 39.6%^‡^ | Post: −23% change in participants endorsing^§^ | NA | NR
Gottlieb, 2018^128^ (Pre-post) | Poor | Referrals | IG2 | All | 4 | Pre: 39.6%^‡^ | Post: −9% change in participants endorsing^§^ | NA | NR
Gottlieb, 2020^129^ (Pre-post) | Poor | Appl support | IG1 | All | 6 | Pre: 77/216 (35.8) | Post: 51/216 (23.6) | NA | <.001
Gottlieb, 2020^129^ (Pre-post) | Poor | Referrals | IG2 | All | 6 | Pre: 88/225 (39.1) | Post: 60/225 (26.6) | NA | <.001
Renaud, 2023^143^ (Pre-post) | Poor | Appl support (+ advisory board) | IG1 | Food insecurity at BL | 12 | Pre: NR (100) | Post: 2247/2929 (76.7) | NA | NR
Renaud, 2023^143^ (Pre-post) | Poor | Appl support | IG2 | Food insecurity at BL | 12 | Pre: NR (100) | Post: 2750/3671 (74.9) | NA | NR
Renaud, 2023^143^ (Pre-post) | Poor | Referrals | IG3 | Food insecurity at BL | 12 | Pre: NR (100) | Post: 1132/1522 (74.4) | NA | NR
Wu, 2019^118^ (Cluster RCT) | Poor | Referrals | IG1 | All | 12 | IG: 50/198 (25.5) | CG: 45/186 (24.2) | 1.04 (0.74 to 1.48) | .59
Berkowitz, 2018^122^ (Pre-post) | Poor | Referrals | IG1 | All | 3 | Pre: 57/141 (40.4) | Post: 53/138 (38.2) | NA | 0.73
Shankar, 2022^136^ (Pre-post) | Poor | Referrals | IG1 | Food insecurity at BL | 12 | Pre: 101/101 (100) | Post: 74/101 (73.3) | NA | NR

* Calculated unadjusted RR

† Study rated moderate (vs. high) risk of bias)

‡ Baseline value is for both groups combined

§ We could not determine whether this was a relative or absolute percent change

Abbreviations: Appl=application; BL=baseline; CG=control group; CI=confidence interval; IG=intervention group; NA=not applicable; NR=not reported; NRSI=non-randomized studies of interventions; NSD=no significant difference; RcoT=randomized crossover trial; RCT=randomized controlled trial; RR=relative risk

Note: Four additional studies reported an outcome related to food security, but not the percent or percent change with food insecurity so are not shown in this table: a continuous measure of food barriers^137,142,144^ and food-medication tradeoffs.^135^ See Appendix D Table 3 for these studies’ results.

Among the remaining studies, neither of the two studies that included control groups—one with food vouchers (n=47)^120^ and one with referrals to food resources (n=4,917)^118^—found statistically significant group differences in food insecurity after 6 to 12 months.

The pre-post studies all trended in the direction of improved food security at followup but had wide-ranging results, with absolute reductions from baseline ranging from 2 to 94 percentage points with food insecurity (median, 23 percentage point reduction). For example, among the studies centered on providing food directly to participants, results ranged from the percent of participants with food insecurity going from 100 percent at baseline to 6 percent at 6-month followup (p-value not reported) in one study, to going from 92 percent at baseline to 84 percent at 3.5-month followup (p-value not reported) in another study. Among all pre-post studies and those reporting only pre-post results, the statistical significance of changes was often either not reported^121,123,125,128,132,136,140,142–144^ or was reported to be not statistically significant.^122,126,130,138^ Three of the pre-post studies reported statistically significant reductions in food insecurity at 6-month followup, however.^129,131,145^

One study did not report the absolute percent with food insecurity, but that food insecurity was reduced by 9 percent and 23 percent among those receiving referrals and application support, respectively, in a study of families with children screened in acute care settings.^128^ Among studies that reported continuous outcomes, reduction from baseline to followup were 0.4^126^ and 1.0^142^ on a 6-point scale, and another study reported a 6-point reduction on the HFSS-18 used as a continuous measure, but the range was not described.^144^

As described above under Risk of Bias, these food insecurity findings are limited by uncertainty in the time windows for the assessment of food insecurity at baseline and followup, which may have the effect of exaggerating the apparent effect size for pre-post studies. There was no apparent pattern of larger or smaller effects according to intervention type (food security only, food security + nutrition education, multidomain) or the type of food support provided (food, vouchers, application support, referrals only).

Food consumption and nutrition outcomes (limited to food security-only interventions). The fair-quality randomized crossover trial reported a number of Healthy Eating Index (HEI) scores, which all indicated healthier eating during the 12-week on-meal phase (Appendix D Table 4).^117^ The HEI total score has a range of 0 to 100, with higher scores indicating healthier eating, and 5-point changes are considered clinically significant, according to the study authors. The HEI total score had a mean (standard deviation [SD]) of 71.3 (7.5) on-meal and 39.9 (7.8) off-meal (p<0.001). HEI scores were also better for intake of vegetables, fruits, greens and beans, whole grains, and empty calories (all had p<0.001).

Eight additional studies with food security-only interventions reported a dietary outcome; all were pre-post studies.^124,127,130,132,133,138,140,142^ Five of these studies included free food and three provided vouchers, and one study included a second study group that received only referrals. All eight studies reported some measure of fruit, vegetable, or fruit and vegetable consumption. Three of these found a statistically significant increase in consumption of fruits, vegetables, or both.^124,130,132,138^ The remaining studies either did not report statistical significance^133,140,142^ or found no significant differences between baseline and followup.^127,138^ One study also reported increased consumption of fiber (3.1 additional g/day) among those who had received at least four of the seven food boxes.^138^ Data were too sparse to draw conclusions about the association between improvements in food security and improved diet, however (the focus of KQ4a).

Health outcomes (limited to food security-only interventions). The fair-quality randomized crossover trial reported less mental health distress on a health-related quality of life measure when on-meal (mean [SD], 5.7 [not reported]) than off-meal (mean [SD], 9.6 [not reported]; I^2^=0.03; Table 18).^117^ No differences between on-meal and off-meal were found for other measures of health-related quality of life (health interference, physical health impacts), self-reported health status, diabetes distress, or depression.

Table 18 Health Outcome Results (Food Security Only Interventions), Key Question 4

Study (design) Quality rating Intervention Component | Outcome | Group | Analyzed | Follow-up (mos) | Group 1; n/N (%) or Mean change^*^ (SD), N | Group 2; n/N (%) or Mean change^*^ (SD), N | Between-group RR^†^ (95% CI) | p-value
Free Food Provided
Berkowitz, 2019^117^ (RcoT)^‡^; Fair | Health status Excellent or Very Good | IG1 | All | 2.8 | On meal: 17/31 (54.8) | Off meal: 19/39 (48.7) | 1.13 (0.72 to 1.77) | 0.50
Berkowitz, 2019^117^ (RcoT)^‡^; Fair | Depression symptoms (Range 0–24, lower is better) | IG1 | All | 2.8 | On meal: −0.9 (NR), 31 | Off meal: −1.0 (NR), 39 | NR | 0.96
Berkowitz, 2019^117^ (RcoT)^‡^; Fair | Diabetes distress (Range 17–102, lower is better) | IG1 | All | 2.8 | On meal: −3.2 (NR), 31 | Off meal: −3.3 (NR), 39 | NR | 0.96
Berkowitz, 2019^117^ (RcoT)^‡^; Fair | HRQoL- health interference (Range 0–30, lower is better) | IG1 | All | 2.8 | On meal: −1.1 (NR), 31 | Off meal: −1.4 (NR), 39 | NR | 0.89
Berkowitz, 2019^117^ (RcoT)^‡^; Fair | HRQoL- mental health (Range 0–30, lower is better) | IG1 | All | 2.8 | On meal: −4.7 (NR), 31 | Off meal: −0.8 (NR), 39 | NR | 0.03
Berkowitz, 2019^117^ (RcoT)^‡^; Fair | HRQoL- physical health (Range 0–30, lower is better) | IG1 | All | 2.8 | On meal: 2.1 (NR), 31 | Off meal: 0.3 (NR), 39 | NR | 0.50
Izumi, 2020^130^ (Pre-post); Poor | Health status Excellent or Very Good | IG1 | All | 5.3 | Pre: 25/48 (52.1) | Post: 33/48 (68.8) | NA | 0.039
Izumi, 2020^130^ (Pre-post); Poor | Feeling down, depressed, or hopeless | IG1 | All | 5.3 | Pre: 29/48 (60.4) | Post: 20/48 (41.7) | NA | 0.035
Kempainen, 2023^140^ (Pre-post); Poor | Health status: good, very good, or excellent | IG1 | All | 5.5 | Pre: 34/106 (32) | Post: 43/106 (41.0) | NA | NR
Kempainen, 2023^140^ (Pre-post); Poor | Depressive symptoms (Range 0-12, lower is better) | IG1 | All | 5.5 | Pre: 2.3 (NR) | Chg: −0.4 (NR), 106 | NA | NR
Kempainen, 2023^140^ (Pre-post); Poor | Diabetes distress (Range 0-12, lower is better) | IG1 | All | 5.5 | Pre: 2.8 (NR) | Chg: −0.3 (NR), 106 | NA | NR
Referrals
Kempainen, 2023^140^ (Pre-post); Poor | Health status: good, very good, or excellent | IG2 | All | 5.5 | Pre: 39/108 (36) | Pre: 35/108 (32.0) | NA | NR
Kempainen, 2023^140^ (Pre-post); Poor | Depressive symptoms (Range 0-12, lower is better) | IG2 | All | 5.5 | Pre: 2.1 (NR) | Chg: −0.1 (NR), 108 | NA | NR
Kempainen, 2023^140^ (Pre-post); Poor | Diabetes distress (Range 0-12, lower is better) | IG2 | All | 5.5 | Pre: 2.6 (NR) | Chg: −0.1 (NR), 108 | NA | NR

* Mean change from baseline values; baseline means are shown in Group 1 column if indicated with “Pre”

† Calculated unadjusted RR

‡ Only study rated moderate (vs. high) risk of bias

Abbreviations: CI=confidence interval; HRQoL=health-related quality of life; IG=intervention group; NA=not applicable; NR=not reported; RcoT=randomized crossover trial; RR=relative risk; SD=standard deviation

Two other pre-post studies reported health outcomes (n=80).^130,140^ One study (n=80) found that, after participating in a 23-week CSA program involving receipt of approximately $100 worth of food for the cost of $22 (payable with SNAP benefits), 67 percent of participants reported that their health status was very good or excellent, up from 52 percent at baseline (p=0.039).^130^ In addition, 42 percent of participants reported feeling down, depressed, or blue at the end of the intervention, compared with 60 percent at baseline (p=0.035). In the other study (n=280) of a 24-week biweekly home delivery of ethnically tailored food boxes, there was minimal impact on depression symptoms or diabetes distress, but the percent reporting their health status to be good, very good, or excellent increased from 32 percent at baseline to 41 percent in the intervention group.^140^ There was a decline in the percent rating their health status as good, very good, or excellent in the group that received only referral for food resources in this study, from 36 percent at baseline to 32 percent at followup.

Physiologic outcomes (limited to food security-only interventions). The fair-quality randomized crossover study found reductions in episodes of hypoglycemia (47% in the intervention group vs. 64% in the control group; I^2^=0.03), but no differences in other laboratory measures related to cardiovascular risk (hemoglobin A1c, high-density lipoprotein cholesterol, low-density lipoprotein cholesterol, triglycerides, total cholesterol, systolic and diastolic blood pressure) or BMI (Table 19).^117^ The other fair-quality study found a smaller increase in BMI among children whose families participated in a mobile food bank than those who did not after 6 months (mean difference in change, −0.68 kg/m^2^ [95% CI, −1.2 to −0.2]; p=0.01).^142^

Table 19 Physiologic Outcome Results (Food Security Only Interventions), Key Question 4

FS Component; Study (design) | Outcome | Analyzed | Follow-up (mos) | Group 1; n/N (%) or Mean change^*^ (SD), N | Group 2; n/N (%) or Mean change^*^ (SD), N | Between-group effect (95% CI) | P-value
Free Food provided
Berkowitz, 2019^117^ (RcoT)^†^; Fair | SBP (mm Hg) | All | 2.8 | On meal: −0.6 (19.2), 31 | Off meal: 2.4 (19.7), 39 | NR | 0.39
Berkowitz, 2019^117^ (RcoT)^†^; Fair | DBP (mm Hg) | All | 2.8 | On meal: −1.5 (10.2), 31 | Off meal: −0.2 (10.8), 39 | NR | 0.29
Berkowitz, 2019^117^ (RcoT)^†^; Fair | LDL cholesterol (mg/dL) | All | 2.8 | On meal: −8.2 (36.8), 31 | Off meal: −4.3 (40.8), 39 | NR | 0.93
Berkowitz, 2019^117^ (RcoT)^†^; Fair | HDL cholesterol (mg/dL) | All | 2.8 | On meal: −0.5 (11), 31 | Off meal: 0.1 (10.5), 39 | NR | 0.59
Berkowitz, 2019^117^ (RcoT)^†^; Fair | Total cholesterol (mg/dL) | All | 2.8 | On meal: 2.9 (45.3), 31 | Off meal: −1 (43.4), 39 | NR | 0.67
Berkowitz, 2019^117^ (RcoT)^†^; Fair | Triglycerides (mg/dL) | All | 2.8 | On meal: NR, 31 | Off meal: NR, 39 | NR | 0.16
Berkowitz, 2019^117^ (RcoT)^†^; Fair | Hemoglobin A1c (%) | All | 2.8 | On meal: −0.2 (1.7), 31 | Off meal: −0.1 (1.6), 39 | NR | 0.57
Berkowitz, 2019^117^ (RcoT)^†^; Fair | Hypoglycemia | All | 2.8 | On meal: 14/31 (46.7) | Off meal: 25/39 (63.9) | RR^c^: 0.7 (0.45 to 1.11) | 0.03
Berkowitz, 2019^117^ (RcoT)^†^; Fair | BMI (kg/m^2^) | All | 2.8 | On meal: −0.9 (6.7), 31 | Off meal: −0.3 (6.8), 39 | NR | 0.93
Kempainen, 2023^140^ (Pre-post, IG1); Poor | LDL cholesterol (mg/dL) | All | 5.5 | Pre: 94.4 (NR), 101 | Chg: −0.5 (NR), 101 | NA | NR
Kempainen, 2023^140^ (Pre-post, IG1); Poor | Hemoglobin A1c (%) | All | 5.5 | Pre: 8.0 (NR), 101 | Chg: −0.4 (NR), 101 | NA | NR
Kempainen, 2023^140^ (Pre-post, IG1); Poor | BMI (kg/m^2^) | All | 5.5 | Pre: 34.2 (NR), 101 | Chg: −0.1 (.), 101 | NA | NR
Ranjit, 2023^141^ (Pre-post); Poor | SBP (mm Hg) | ≥1 visit to food pantry | 6 | Pre: NR | Chg: −1.8 (11.7), 213 | NA | NR
Ranjit, 2023^141^ (Pre-post); Poor | DBP (mm Hg) | ≥1 visit to food pantry | 6 | Pre: NR | Chg: −0.9 (8.8), 213 | NA | NR
Ranjit, 2023^141^ (Pre-post); Poor | LDL cholesterol (mg/dL) | ≥1 visit to food pantry | 6 | Pre: NR | Chg: −5.4 (22.2), 112 | NA | NR
Ranjit, 2023^141^ (Pre-post); Poor | Hemoglobin A1c (%) | ≥1 visit to food pantry | 6 | Pre: NR | Chg: −0.5 (2), 389 | NA | NR
Ranjit, 2023^141^ (Pre-post); Poor | BMI (kg/m^2^) | ≥1 visit to food pantry | 6 | Pre: NR | Chg:.1 (2.4), 342 | NA | NR
Wetherill, 2018^138^ (Pre-post); Poor | DBP (mm Hg) | High BP at BL and received 4+ boxes | ≤7 | Pre: 90.9 (NR), 17 | Post: −7 (.), 17 | NA | <.05
Woo Baidal, 2023^142^ (NRSI)^‡^; Fair | BMI (kg/m^2^) (Child’s) | All | 6 | IG: 0.7 (1.8), 44 | CG: 1 (1.7), 132 | Mean Diff in Change: −0.68 (−1.2 to −0.2) | 0.01
Vouchers
Xie, 2021^139^ (Pre-post); Poor | SBP (mm Hg) | All | 12 | Pre: 132.5 (16.3) | Post: NR, 353 | NA | 0.51
Xie, 2021^139^ (Pre-post); Poor | Hemoglobin A1c (%) | All | 12 | Pre: 8.3 (2.2) | Post: NR, 353 | NA | 0.53
Xie, 2021^139^ (Pre-post); Poor | BMI (kg/m^2^) | All | 12 | Pre: 36.2 (9.1) | Post: NR, 353 | NA | 0.54
Application support
Morales, 2016^119^ (NRSI); Poor | SBP (mm HG/wk) | All | Trend across pregnancy | NR, 145 | NR, 145 | Unstd ES: −0.076 (NR) | 0.14
Morales, 2016^119^ (NRSI); Poor | DBP (mm HG/wk) | All | Trend across pregnancy | | | Unstd ES: −0.039 (NR) | 0.33
Morales, 2016^119^ (NRSI); Poor | Blood glucose (mg/dL/wk) | All | Trend across pregnancy | | | Unstd ES: −0.009 (NR) | 0.91
Referrals
Kempainen, 2023^140^ (Pre-post, IG2); Poor | LDL cholesterol (mg/dL) | All | 5.5 | Pre: 97.2 (NR), 114 | Chg: −1.7 (NR), 114 | NA | NR
Kempainen, 2023^140^ (Pre-post, IG2); Poor | Hemoglobin A1c (%) | All | 5.5 | Pre: 7.9 (NR), 114 | Chg: −0.1 (NR), 114 | NA | NR
Kempainen, 2023^140^ (Pre-post, IG2); Poor | BMI (kg/m^2^) | All | 5.5 | Pre: 34.8 (NR), 114 | Chg: −0.3 (NR), 114 | NA | NR

* Mean change from baseline values

† Study rated moderate (vs. high) risk of bias)

‡ Calculated unadjusted RR

Abbreviations: BP=blood pressure; BL=baseline; BMI=body mass index; CI=confidence interval; DBP=diastolic blood pressure; HDL=high-density lipoprotein; IG=intervention group; LDL=low-density lipoprotein; NA=not applicable; NR= not reported; NRSI=non-randomized studies of interventions; RcoT=randomized crossover trial; RR=relative risk; SD=standard deviation; SPB=systolic blood pressure; Unstd ES=unstandardized effect size

Five other studies also reported one or more physiologic outcomes (Table 19).^119,138–141^ One of these, a nonrandomized controlled study that provided referrals and application support to community and federal food resources during pregnancy (n=290), found no group differences in blood pressure or glucose levels at the end of pregnancy.^119^ One pre-post study (n=80) found a statistically significant improvement in diastolic blood pressure of 7 mm Hg between baseline and up to 7 months later among participants who initially had high blood pressure and had received at least four of the seven monthly food boxes.^138^ Other physiologic outcomes were not shown, nor was diastolic blood pressure reported for the full sample. Another pre-post study that provided produce vouchers to people with diabetes (n=353) found no change in hemoglobin A1c, systolic blood pressure, or BMI.^139^ The remaining pre-post studies found minimal absolute change in blood pressure, low-density lipoprotein cholesterol, or BMI and did not report on the statistical significance of the changes.^140,141^

Acute healthcare utilization (limited to food security-only interventions). One pre-post study (n=340) reported on change in the proportion of patients with ED visits and hospital stays 1 year after implementing an intervention that provided biweekly food boxes for 1 year to primary care patients with food insecurity.^134^ After 1 year, the percent of patients enrolled in the intervention with an ED visit or hospital stay did not differ from baseline, although findings trended in the direction of benefit (ED visits: 48% at baseline, 28% at followup; hospital stays: 11.7% at baseline, 10.2% at followup; Table 20).

Table 20 Healthcare Utilization Results (Food Security Only Interventions), Key Question 4

Food security component; Study (design) Quality rating | Outcome | Analyzed | Follow-up (mos) | Group 1; n/N (%) | Group 2; n/N (%) | p-value
Free food provided
Scher, 2022^134^ (Pre-post); Poor | ED visits | All | 12 | Pre: 123/256 (48.0) | Post: 122/256 (27.7) | NSD^*^
Scher, 2022^134^ (Pre-post); Poor | Hospitalizations | All | 12 | Pre: 30/256 (11.7) | Post: 26/256 (10.2) | NSD^*^

* Exact p-value not provided

Abbreviations: ED=emergency department; NSD=no significant difference

Patient decision making (limited to food security only interventions). The fair-quality randomized crossover study found no differences in cost-related medication underuse or food-medication tradeoffs during the on-meal and off-meal phases of the study (Table 21).^117^ One other pre-post study reported on the likelihood that individuals had to choose between purchasing food and medication associated with their intervention that included diabetes-appropriate food boxes, diabetes self-management support, glucose monitoring, and healthcare referrals. This study found statistically significant reductions from baseline in the likelihood of needing to make a tradeoff between food or medication, both overall and among people with an hemoglobin A1c of 7.5 percent or greater.^135^ One additional pre-post study found minimal absolute change in a continuous measure of cost-related medication underuse and did not report the statistical significance of the change.^140^

Table 21 Healthcare Decision-Making Results (Food Security Only Interventions), Key Question 4

FS Component; Study (design), Quality rating | Outcome | Measure | Analyzed | Follow-up (mos) | Group 1; n/N (%) | Group 2; n/N (%) | Between-group RR^*^ (95% CI) | p-value
Free food provided
Berkowitz, 2019^117^ (RcoT), Fair | Food-medication tradeoffs | Items derived from Ippolito et al. | All | 2.8 | On-meal: 9/31 (29.0) | Off-meal: 9/39 (23.1) | 1.26; (0.57 to 2.78) | 0.12
Berkowitz, 2019^117^ (RcoT), Fair | Cost-related medication underuse | Items derived from National Health Interview Survey | All | 2.8 | On-meal 7/31 (22.6) | Off-meal: 11/39 (28.2) | 0.8; (0.35 to 1.82) | 0.52
Kempainen, 2023^140^ (Pre-post, IG1), Poor | Cost-related medication underuse | Self-report (details NR) (Range 0-5, Lower is better) | All | 5.5 | Pre: 0.4 (NR), 106 | Chg: −0.1 (NR), 106 | NA | NR
Seligman, 2015^135^ (Pre-post), Poor | Food-medication tradeoffs | Self-report (details NR) | All | 6 | Pre: 47/641 (7.3) | Post: 36/641 (5.6) | NA | <0.001
Seligman, 2015^135^ (Pre-post), Poor | Food-medication tradeoffs | Self-report (details NR) | Uncontrolled HbA1c (>=7.5%) at baseline | 6 | Pre: 51/379 (13.5) | Post: 40/379 (10.6) | NA | <0.001
Referrals
Kempainen, 2023^140^ (Pre-post, IG2), Poor | Cost-related medication underuse | Self-report (details NR) (Range 0-5, Lower is better) | All | 5.5 | Pre: 0.3 (NR), 108 | Chg: 0 (NR), 108 | NA | NR

* Calculated unadjusted RR

Abbreviations: Chg=change; CI=confidence interval; IG=intervention group; NA=not applicable; NR=not reported; RCoT=randomized crossover trial; RR=relative risk

## KQ4a What Are the Effects of Improvements in Food Security Outcomes on Intermediate and Health Outcomes?

None of the included studies reported on impact of improved food security on intermediate or health outcomes.

## KQ4b What Are the Effects of Improvements in Intermediate Outcomes on Health Outcomes?

None of the included studies reported the impact of improved intermediate outcomes on health outcomes.

## KQ5 What Are the Harms or Unintended Consequences of Healthcare-Related Interventions to Address Food Insecurity?

One fair-quality study included for KQ4 reported that one person experienced gastrointestinal symptoms during the on-meals phase, but there were no other adverse events.^117^ None of the other included studies reported on harms or potential harms of their interventions. We identified no pattern of results showing paradoxical worsening of any outcome associated with the included interventions.